# Bibliography

Acharya R K, Upadhyay B N, Dwivedi L D. Dietary management in prameha. Ancient Sci Life. 1996;15(3):176-89.
Ackerknecht EH. A short history of medicine. Baltimore: Johns Hopkins University Press;1982.
Agrawal P, Rai V, Singh R B. Randomized placebo-controlled single-blind trial of holy basil leaves in patients with non-insulin-dependent diabetes mellitus. Int J Clin Pharmacol Ther. 1996;34:406-9. [pmid: 8880292].
Ahmed F, Khalid P, Khan M M, et al. Hypoglycemic activity of Pterocarpus marsupium wood. J Ethnopharmacol. 1991;35(1):71-75. [pmid: 1753796].
Ajgaonkar S S. Herbal drugs in the treatment of diabetes: a review. Int Diabetes Fed Bull. 1979;24:10-17.
Akhtar M S. Hypoglycaemic activities of some indigenous medicinal plants traditionally used as antidiabetic drugs. J Pak Med Assoc. 1992;42(11):271-277. [pmid: 1479640].
Akhtar MS. Trial of Momordica charantia Linn. powder in patients with maturity onset diabetes. J Pak Med Assoc Apr 1982;106–107.
Al-Habori M, Raman A. Antidiabetic and hypocholesterolaemic effects of fenugreek. Phytother Res. 1998;12:233-242.
Allied and Complementary Medicine [database online]. London (UK): The British Library; 1985-. Updated monthly. Available from: DIALOG, Cary, NC; DataStar, Cary, NC; VND Karolinska Institute Library and Information Center/Karolinska Institutets Bibliotek och Informationscentral (KIBIC), Medical Information, Stockholm, Sweden; DIMDI (Deutsches Institut fuer Medizinische Dokumentation und Information), Cologne, Germany.
Alternative Med Rev. Gymnema sylvestre 1999;4(1)46–47
Azad Khan AK, Akhtar S, Mahtab H. Coccinia indica in the treatment of patients with diabetes mellitus. Bangladesh Med Res Counc Bull 1979 Dec;5(2):60–6.
Baghel MS. Researches in Ayurveda: A classified directory of all India P. G. and Ph.D. theses of Ayurveda. Jamnagar (India): MRIDU Ayurvedic Publications and Sales; 1997.
Bailey C J, Day C. Traditional plant medicines as treatments for diabetes. Diabetes Care. 1989;12(8):553-564. [pmid: 2673695].
Balasubramaniam K, Arasaratnam V, Nageswaran A, et al. Studies on the effect of Gymnema sylvestre on diabetics. J Natl Sci Counc Sri Lanka. 1992;20(1):81-89.
Balasubramaniam K, Arasaratnam V, Seevaratnam S, et al. Hypoglycaemic effect of Gymnema sylvestre on diabetic patients. Jaffna Med J. 1988;23:49-53.
Baldwa V S, Bhandari C M, Pangaria A, et al. Clinical trial in patients with diabetes mellitus of an insulin-like compound obtained from plant source. Ups J Med Sci. 1977;82(1):39-42. [pmid: 20078273].
Barnett RA, Barone J. Ayurvedic medicine: Ancient roots, modern branches. Concorp Management, 1996.
Baskaran K, Ahamath B K, Shanmugasundaram K R, et al. Antidiabetic effect of a leaf extract from Gymnema sylvestre in non-insulin-dependent diabetes mellitus patients. J Ethnopharmacol. Oct. 1990;30(3):295-300. [pmid: 2259217].
Bhandari U, Grover J K. A reappraisal of clinical studies on the comparative influences of three indigenous plant drugs in diabetes mellitus. Hamdard Medicus. 1998;41(2):9-15.
Bharti MS and Singh RH. Constitutional study of patients of diabetes mellitus vis-à-vis Madhumeha. Ancient Sci Life 1995;15(1)35–42.
Blumenthal M, Goldberg A, Brinkman J. Herbal medicine: Expanded German Commission E. Austin (TX): American Botanical Council; 2000, 130–133.
Bone K. Clinical applications of Ayurvedic and Chinese herbs: Monographs for the western practitioner. Warwick (Queensland, Australia): Phytotherapy Press; 1996.
Brahmchari H D, Augusti K T. Orally effective hypoglycemic principles from Coccinia indica. J Pharm Pharmacol. 1963;15:411-412. [pmid: 14014882].
Brala P M, Hagen R L. Effects of sweetness perception and caloric value of a preload on short term intake. Physiol Behav. 1983;30:1-9. [pmid: 6836034].
CAB HEALTH [database online]. Wallingford, (UK): CAB International; 1973-. Updated monthly. Available from: DIALOG Corp., Cary, NC; DataStar, Cary, NC; DIMDI (Deutsches Institut fuer Medizinische Dokumentation und Information), Cologne, Germany.
Castiglioni A. A history of medicine. 2nd ed. Krumbhaar EB, translator and editor. New York: Alfred A. Knopf; 1947.
Chakravarthy B K, Gupta S, Gambhir S S, et al. Pancreatic beta-cell regeneration — A novel antidiabetic mechanism of Pterocarpus marsupium, Roxb. Indian J Pharmacol. 1980;12(2):123-127.
Chandola H M, Tripathi S N. Diagnosis of 20 subtypes of prameha based on physical and chemical examination of urine in proved cases of diabetes mellitus. J Res Ayurveda and Siddha. Jun. 1980;1(2):224-237.
Chandola HM, Tripathi SN, Udupa KN. Effect of C. tamala on plasma insulin vis-a-vis blood sugar in patients of diabetes mellitus. J Res Ayurveda and Siddha 1980b Sept;1(3):345–357.
Chandola HM, Tripathi SN, Udupa KN. Hypoglycaemic response of C. tamala in patients of maturity onset (insulin independent) diabetes. J Res Ayurveda and Siddha 1980a June;1(2):275–290.
Chandola H M, Tripathi S N, Udupa K N. Variations in the progression of maturity onset diabetes according to body constitution. Ancient Sci Life. 1994;13(3&4):293-301.
Chattopadhyay RR, Medda C, Das S, et al. Hypoglycemic and antihyperglycemic effect of Gymnema sylvestre leaf extract in rats. Fitoterapia 1993;LXIV(5):450–4.
Chattopadhyay R R. Possible mechanism of antihyperglycemic effect of Gymnema sylvestre leaf extract. Part 1. Gen Pharmacol. 1998;31(3):495-6. [pmid: 9703226].
Chaturvedi G N, Subramaniyam P R, Tiwari S K, et al. Experimental and clinical studies on diabetic mellitus evaluating the efficacy of an indigenous oral hypoglycaemic drug Arani (Clerodendron phlomidis). Ancient Sci Life. 1983;3(4):216-224.
Chowdhary DP, Dua M, Bharti, et al. Hypoglycaemic effect of a coded formulation: Aysuh-82. J Res Ayurveda and Siddha 1998 July-Dec 31;XIX(3–4):107–115.
Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale (NJ): L. Erlbaum Associates; 1988.
Dahanukar S A, Thatte U M. Current status of Ayurveda in phytomedicine. Phytomedicine. 1997;4(4):359-368.
Dash VB. Materia medica of Indo-Tibetan medicine. Delhi: MDIA Classics India Publications; 1987,10–11.
Dateo Jr. GP, Long Jr. L. Gymnemic acid, the antisaccharine principle of Gymnema sylvestre. Studies on the isolation and heterogeneity of gymnemic acid A_1_. J Agric Food Chem 1973 Sept-Oct;21:899–903.
De Smet P A G M. The role of plant-derived drugs and herbal medicines in healthcare. Drugs. 1997;54(6):801-840. [pmid: 9421691].
Dev S. Ancient-modern concordance in Ayurvedic plants: Some examples. Environ Health Perspect. 1999;107(10):783-789. [pmid: 10504143].
Ernst E. Plants with hypoglycemic activity in humans. Phytomedicine. 1997;4(1):73-78.
Evans WC. Trease and Evans' pharmacognosy. 14th ed. Philadelphia: WB Saunders Co. Ltd.; 1996.
Fendall R. Ayurvedic medicine and primary health care. World Health Forum. 1982;3(1):90-94.
Fletcher J L, Dingley A J, Smoth R, et al. High-resolution structure of gurmarin, a sweet-taste-suppressing plant polypeptide. Eur J Biochem. 1999;264:525-533. [pmid: 10491100].
Frank R A, Mize S J S, Kennedy L M, et al. The effect of Gymnema sylvestre extracts on the sweetness of eight sweeteners. Chem Senses. 1992;17(5):461-479.
Frawley D, Lad V. An Ayurvedic guide to herbal medicine. 2nd edition. Twin Lakes (WI): Lotus Press; 1988.
Gerson, S. Personal communication. 7 Nov 2000.
Gori M, Campbell R K. Natural products and diabetes treatment. Diabetes Educator. 1998;24(2):201-208. [pmid: 9555359].
Goyal DK, Tiwari SK. Study on sadabahar (Vinca rosea Linn) in madhumeha (diabetes mellitus). J Res Ayurveda and Siddha 1999 Jan-June 30;XX(1–2):93–100.
Gupta R. Indian herbs and herbal raw material Ctime-tested remedies for all ailments. Indian Horticulture 1990 Jan-Mar:39–43.
Gupta SN, Mishra SK, Singh G. Correlations between blood sugar levels and some biochemical as well as Ayurvedic phenomena in the patients of madhumeha (diabetes mellitus). J Res Ayurveda and Siddha 1981 Mar;II(1):11–16.
Handa S S, Chawla A S, Maninder N A. Hypoglycaemic plants—a review. Fitoterapia. 1989;15(3):195-224.
Hellekant G, Hagstrom E C, Kasahara Y, et al. On the gustatory effects of miraculin and gymnemic acid in the monkey. Chem Senses and Flavor. 1974;1:137-145.
Hii S C T, Howell S L. Effects of epicatichin on rat islets of Langerhans. Diabetes. 1984;33:291-296. [pmid: 6365662].
Hossain M Z, Shibib B A, Rahman R. Hypoglycemic effects of Coccinia indica: Inhibition of key gluconeogenic enzyme, glucose-6-phosphatase. Indian J Exp Biol. 1991;30:418-420. [pmid: 1334043].
Imoto T, Miyasaka A, Ishima R, et al. A novel peptide isolated from the leaves of Gymnema sylvestre. Part 1. Characterization and its suppressive effect on the neural responses to sweet taste stimuli in the rat. Comp Biochem Physiol. 1991;100A(2):309-314.
Indian Council for Medical Research (ICMR). Role of fenugreek seeds in diabetes mellitus. ICMR Bulletin. 1987;17(9):79-93.
Indian Council for Medical Research, ICMR Collaborating Centres, Central Biostatistical Monitoring Unit, Chennai & Central Technical Co-ordinating Unit, ICMR New Delhi. Flexible dose open trial of Vijayasar in cases of newly-diagnosed non-insulin-dependent diabetes mellitus. Indian J Med Res 1998 July;108:24–29.
International Society of Alternative Medicine. Ayurveda. Altern Med. 1987;2(2):73-94.
Ivorra M D, Paya M, Villar A. A review of natural products and plants as potential antidiabetic drugs. J Ethnopharmacol. 1989;27:243-275. [pmid: 2693840].
J Res Ayurveda and Siddha. Clinical and experimental evaluation of endocrine response of herbal drugs. (Monograph) 1992;13(3–4):174–178.
Jadad A R, Moor A R, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jain SC, Agrawal M, Sharma RA. The genus Trigonella—Phytochemistry and biology. Ancient Sci Life 1996;XVI:108–117.
Jain AK, Chakraborty D. A clinical study on a herbal antidiabetic product, a preliminary report. Indian Med Gaz Oct 1987;350–351.
Jain SK, DeFilipps RA. Medicinal plants of India. Algonac (MI): Reference Publications, Inc.; 1991.
Jellin JM, Batz F, Hitchens K. Pharmacist's letter/prescriber's letter Natural Medicines Comprehensive Database. Stockton (CA): Therapeutic Research Facility; 1999.
Kamble SM, Jyotishi GS, Kamalakar PL, et al. Efficacy of Coccinia indica W. & A. in diabetes mellitus. J Res Ayurveda and Siddha 1996 Jan-June 30;XVII(1–2):77–84.
Kamble S M, Kamlakar P L, Vaidya S, et al. Influence of Coccinia indica on certain enzymes in glycolytic and lipolytic pathway in human diabetes. Indian J Med Sci. Apr. 1998;52(4):143-146. [pmid: 9770877].
Kamei K, Takano R, Miyasaka A, et al. Amino acid sequences of sweet-taste-suppressing peptide (gurmarin) from the leaves of Gymnema sylvestre. J Biochem (Tokyo). 1992;111:109-112. [pmid: 1607357].
Kapoor LD. CRC handbook of Ayurvedic medicinal plants. Boca Raton (FL): CRC Press, Inc.; 1990.Kar CA, Upadhyay BN, Ojha D. Prognosis of prameha on the basis of insulin level. Ancient Sci Life 1997 April; Vol. XVI: 277–283.
Kar CA, Upadhyay BN, Ojha D. Prognosis of prameha on the basis of insulin level. Ancient Sci Life 1997 April; Vol. XVI: 277–283.
Katsukawa H, Imoto T, Ninomiya Y. Induction of salivary gurmarin-binding proteins in rats fed Gymnema-containing diets. Chem Senses. 1999;24:387-392. [pmid: 10480674].
Kedar P, Chakrabarti CH. Blood sugar, blood urea and serum lipids as influenced by Gurmar preparation, Pterocarpus marsupium and Tamarindus indica in diabetes mellitus. Maharashtra Med J Sept 1981;XXVIII(6)165–169.
Kehoe WA. Fenugreek for type 2 diabetes. Pharmacist's Letter. 1998; Detail No. 150209:1–3.
Khajuria S, Thomas J. Traditional Indian beliefs about the dietary management of diabetes - An exploratory study of the implications for the management of Gujarati diabetics in Britain. J Hum Nutr Diet. 1992;5(5):311-321.
Khanna P, Jain S C, Panagariya A, et al. Hypoglycemic activity of polypeptide-p from a plant source. J Nat Prod. 1981;44(6):648-655. [pmid: 7334382].
Khare AK, Tondon RN, Tewari JP. Hypoglycaemic activity of an indigenous drug (Gymnema sylvestre, “Gurmar”) in normal and diabetic persons [letter]. Indian J Physiol Pharmacol 1983 July-Sept 30;27(3):257–258.
Kohli KR, Singh RH. A clinical trial of jambu (Eugenia jambolana) in non-insulin dependant diabetes mellitus. J Res Ayurveda and Siddha 1993 Sept-Dec 31;XIV(304):89–97.
Kothe A, Uppal R. Antidiabetic effects of Gymnema sylvestre in NIDDM—a short study. Indian J Homeopath Med 1997;32(1–2):61–2, 66.
Kumar N, Kumar A. A clinical trial of M-93 compound in the management of madhumeha (diabetes mellitus). J Res Ayurveda and Siddha 1995 July-Dec 31;XVI(3–4):102–107.
Kumar N, Kumar A, Sharma ML. Clinical evaluation of single and herbo-mineral compound drugs in the management of madhumeha. J Res Ayurveda and Siddha 1999 Jan-June 30;XX(1–2):1–9.
Kuppurajan K, Seshadri C, Revathi R, et al. Hypoglycaemic effect of Coccinia indica in diabetes mellitus. Nagarjun. Jan. 1986;29(5):1-4.
Kuppu Rajan K, Srivatsa A, Krishnaswami C V, et al. Hypoglycemic and hypotriglyceridemic effects of methika churna (fenugreek). Antiseptic. 1998;95(3):78-79.
Kutumbiah P. Ancient Indian medicine. Bombay: Orient Longmans; 1962.
Lad V. Ayurvedic medicine. In: Jonas WB and Levin JS, editors. Essentials of complementary and alternative medicine. New York: Lippincott Williams & Wilkins; 1999; 200–215.
Lad V. Ayurveda: The science of self-healing. 2nd ed. Wilmot (WI): Lotus Press; 1985.
Lad V. An introduction to Ayurveda. Alternative Therapies in Health and Medicine 1995 July 31; 1(3): 57–63.
Lawrence Review of Natural Products. Fenugreek. 1996; July:1–3.
Lawrence Review of Natural Products. Gymnema. 1993; Aug:1–2.
Leatherdale BA, Panesar RK, Singh G, et al. Improvement in glucose tolerance due to Momordica charantia (karela). Br Med J 1981 June 6;282(6279)1823–1824.
Lenz E. Bitter melon helps type II diabetics keep blood sugar in balance. Herbs for Health 1998; Sept-Oct:26.
Lenz E. Bitter melon. Herbs for Health 1998; Nov-Dec:16.
Lewis WH, Elvin-Lewis MPF. Medical botany: Plants affecting man's health. New York: Wiley; 1977.
Liu H M, Kiuchi F, Tsuda Y. Isolation and structure elucidation of gymnemic acids, antisweet principles of Gymnema sylvestre. Chem Pharm Bull (Tokyo). 1992;40(6):1366-1375. [pmid: 1327559].
Lodha R, Bagga A. Traditional Indian systems of medicine. Ann Acad Med Singapore. June. 2000;29(1):37-41. [pmid: 10748962].
Magner LN. A history of medicine. New York: Marcel Dekker, Inc.; 1992.
Maji D. , Singh A.K. Clinical trial of D-400, a herbomineral preparation in diabetes mellitus. J Diabetic Assoc India. 1995;35(1):1-4.
Manickam M, Ramanathan M, Jahromi M A, et al. Antihyperglycemic activity of phenolics from Pterocarpus marsupium. J Natural Prod. 1997;60(6):609-610.
MANTIS (Manual, Alternative and Natural Therapy) [database online]. Denton (TX): Action Potential; 1880-. Updated monthly. Available from: DIALOG, Cary, NC; DataStar, Cary, NC; Ovid Technologies, New York, NY; Action Potential, Denton, TX.
Marles R J, Farnsworth N R. Antidiabetic plants and their active constitutents. Phytomedicine. 1995;2(2):137-189.
Marvah B, Singh G. A clinical study on the role of an indigenous drug Avartaki (Cassia auriculata). Ayu 1990 July-Aug;11(7–10):5 1–13.
Mathew PT, Augusti KT. Hypoglycaemic effects of onion, Allium cepa Linn. on diabetes mellitus—A preliminary report. Indian J Physiol Pharmacol Oct/Dec 1975;19(4):213–217.
Mishra L, Singh B, Dagenais S. Ayurveda: A historical perspective and principles of the traditional healthcare system in India. Altern Ther Health Med 2001b Mar;7:36–42.
Mishra L, Singh B, Dagenais S. Healthcare and disease management in Ayurveda. Altern Ther Health Med 2001a Mar;7:44–50.
Moher D, Pham B, Jones A, et al. Does quality of reports of randomized trials affect the estimates of intervention efficacy reported in meta-analysis?. Lancet. 1998;352:609-13. [pmid: 9746022].
Nadkarni AK, Nadkarni KM. Indian materia medica. 3rd ed. Bombay: Popular Prakashan; 1976.
Nagaraju N, Prasad M, Gopalakrishna G, et al. Blood sugar lowering effect of Pterocarpus santalinus (red sandal) wood extract in different rat models. Int J Pharmacognosy. 1991;29(2):141-144.
Nanda GC, Chopra KK, Sahu DP, et al. Nishamalaki in madhumeha (NIDDM): A clinical study. J Res Ayurveda and Siddha 1998 Jan-June 30;XIX(1–2):34–40.
Nande CV, Kale PM, Wagh SY, et al. Effect of jambu fruit pulp (Eugenia jambolana Lam) on blood sugar levels in healthy volunteers and diabetics. J Res Ayurveda and Siddha 1983 Mar-Dec 31;IV(1–4):1–5.
Okabayashi Y, Tani S, Fujisawa T, et al. Effect of Gymnema sylvestre R. Br. on glucose homeostasis in rats. Diabetes Res Clin Pract. 1990;9(1990):143-148. [pmid: 1695875].
Pandey VN, Rajagopalan SS, Chowdhary DP. An effective Ayurvedic hypoglycemic formulation. J Res Ayurveda and Siddha 1995 Jan-June 30;XVI(1–2):1–14.
Pandya MA, Nirmal BM, Mistry IU. Role of pathya ahara in the treatment of madhumeha: A clinical study. Ayu 1990 Nov-Dec;11(11–12):1–7.
Persaud S J, Al-Majed H, Raman A, et al. Gymnema sylvestre stimulates insulin release in vitro by increased membrane permeability. J Endocrinol. 1999;163(2):207-212. [pmid: 10556769].
Porter R. The greatest benefit to mankind: A medical history of humanity. New York: WW Norton & Co; 1997.
Prakash A O, Mathur S, Mathur R. Effect of feeding Gymnema sylvestre leaves on blood glucose in beryllium nitrate treated rats. J Ethnopharmacol. 1986;18:143-146. [pmid: 3560992].
Raghuram T C, Sharma R D, Sivakumar B, et al. Effect of fenugreek seeds on intravenous glucose disposition in non-insulin-dependent diabetic patients. Phytother Res. 1994;8:83-86.
Rai M K. Herbal medicines in India: Retrospect and prospect. Fitoterapia. 1994;65(6):483-491.
Rajasekharan S, Tuli S N. Vijaysar, Pterocarpus maruspium, in the treatment of madhumeda (diabetes mellitus): A clinical trial. J Res Indian Med Yoga. May. 1976;11(2):9-15.
Rajurkar N S, Pardeshi B M. Analysis of some herbal plants from India used in the control of diabetes mellitus by NAA and AAS techniques. Appl Radiat Isot. 1997;48(8):1059-1062. [pmid: 9394437].
Raman A, Lau C. Anti-diabetic properties and phytochemistry of Momordica charantia (curcubitacea). Phytomedicine. 1996;2(4):349-62.
Raman A, Skett P. Traditional remedies and diabetes treatment. In: Prendergast HDV, Etkin NL, Harris DR, Houghton PJ, editors. Plants for food and medicine. London: Royal Botanic Gardens, Kew 1998; 361–372.
Ray J W, Shadish W R. How interchangeable are different estimators of effect size?. J Consult Clin Psychol. 1996;64:1316-1325. [pmid: 8991318].
Rege N N, Thatte U M, Dahanukar S A. Adaptogenic properties of six rasayana herbs used in Ayurvedic medicine. Phytother Res. 1999;13:275-291. [pmid: 10404532].
Sadhukhan B, Roychowdhury U, Banerjee P, et al. Clinical evaluation of a herbal antidiabetic product. J Indian Med Assoc. Apr. 1994;92(4):115-7. [pmid: 8083548].
Sanyal PK. A story of medicine & pharmacy in India: Pharmacy 2000 years ago and after. Calcutta: Shri Amitava Sanyal; 1964.
Sathe R V. Diabetics in -retrospect and prospect. J Assoc Physicians India. Jun. 1969;17(6):387-398. [pmid: 4899851].
Savnur HV. Ayurvedic materia medica. Reprint ed. Delhi: Sri Satguru Publications; 1988.
Sepaha G S, Bose S N. Clinical observations on the antidiabetic properties of Pterocarpus marsupium and Eugenia jambolana. J Indian Med Assoc. Dec. 1956;27(11):388-391. [pmid: 13398630].
Shah V. Diabetes mellitus in Indian medicine. Varansi (India): Chaukhambha Orientalia; 1995.
Shankar VR, Aggarwal MP. Clinical studies of abraga (mica) chendooram in the management of diabetes mellitus (neerazhivu). J Res Ayurveda and Siddha 1988 Mar-June 30;IX(1–2):38–45.
Shankar R, Singhal RK. Clinical assessment of the effects of sandana (sandal) podi-a in the treatment of diabetes mellitus (neerazhiv). J Res Ayurveda and Siddha 1994 Sept-Dec 31;XV(3–4):89–97.
Shankar R, Singhal RK. Clinical studies of the effect of abraga (mica) chendooram in the treatment of diabetes mellitus (neerazhivu). J Res Ayurveda and Siddha 1995 July-Dec 31;XVI(3–4):108–117.
Shanmugasundaram E R, Gopinath K L, Shanmugasundaram K R, et al. Possible regeneration of the islets of Langerhans in streptozotocin-diabetic rats given Gymnema sylvestre leaf extracts. J Ethnopharmacol. 1990a;30:265-279. [pmid: 2259215].
Shanmugasundaram ER, Rajeswari G, Baskaran K, et al. Use of Gymnema sylvestre leaf extract in the control of blood glucose in insulin-dependent diabetes mellitus. J Ethnopharmacol 1990b Oct;30(3):281–94.
Shanmugasundaram ER, Venkatasubrahmanyam M, Vijendran N, et al. Effect of an isolate from Gymnema sylvestre, R.Br. in the control of diabetes mellitus and the associated pathological changes. Ancient Sci Life 1988;VII(3 and 4):183–194.
Shanmugasundaram K R, Panneerselvam C, Samudram P, et al. Enzyme changes and glucose utilisation in diabetic rabbits: The effect of Gymnema sylvestre, R Br. J Ethnopharmacol. Mar. 1983;7(2):205-234. [pmid: 6865451].
Shanmugasundaram K R, Panneerselvam C, Samudram P, et al. The insulinotropic activity of Gymnema sylvestre, R.Br. An Indian medical herb used in controlling diabetes mellitus. Pharm Res Communications. May. 1981;13(5):475-486.
Sharma H, Clark C. Contemporary Ayurveda: Medicine and research in Maharishi Ayur-Veda. (Micozzi M, series editor. Medical guides to complementary and alternative medicine.) New York: Churchill Livingstone; 1997.
Sharma H, Clark C. Maharishi Ayurveda. In: Micozzi M, editor. Fundamentals of complementary and alternative medicine. New York: Churchill Livingstone; 1996.
Sharma K K, Gupta R K, Gupta S, et al. Antihyperglycemic effect of onion: Effect on fasting blood sugar and induced hyperglycemia in man. Indian J Med Res. 1977;65:422-429. [pmid: 336527].
Sharma R D. Effect of fenugreek seeds and leaves on blood glucose and serum insulin responses in human subjects. Nutrition Research. 1986;6(12):1353-1364.
Sharma R D, Raghuram T C. Hypoglycaemic effect of fenugreek seed in non-insulin dependent diabetic subjects. Nutr Res. 1990;10:731-739.
Sharma R D, Raghuram T C, Rao N S. Effect of fenugreek seeds on blood glucose and serum lipids in type I diabetes. Euro J Clin Nutrition. 1990;44:301-306.
Sharma R D, Sarkar A, Hazra D K, et al. Hypolipidaemic effect of fenugreek seeds: A chronic study of non-insulin dependent diabetic patients. Phytotherapy Res. 1996b;10(4):332-334.
Sharma R D, Sarkar A, Hazra D K, et al. Use of fenugreek seed powder in the management of non-insulin dependent diabetes mellitus. Nutr Res. 1996a;16:1331-1339.
Shibib B A. Hypoglycaemic activity of Coccinia indica and Momordica charantia in diabetic rats: Depression of the hepatic gluconeogenic enzymes glucose-6-phosphatase and fructose-1,6-bisphosphatase and elevation of both liver and red-cell shunt enzyme glucose-6-phosphate dehydrogenase. Biochem. 1993;292:267-270.
Shimizu K, Iino A, Nakajima J, et al. Suppression of glucose absorption by some fractions extracted by Gymnema sylvestre leaves. J Vet Med Sci. 1997;59(4):245-251. [pmid: 9152931].
Sigerist HE. A history of medicine: Early Greek, Hindu and Persian medicine. Oxford: Oxford University Press; 1961.
Singh N, Singh S P, Vrat S, et al. A study on the anti-diabetic activity of Coccinia indica in dogs. Indian J Med Sci. 1985;39:27-29. [pmid: 3997215].
Sircar A R, Ahuja R C, Natu S M, et al. Hypoglycemic, hypolipidemic and general beneficial effects of an herbal mixture MA-471. Altern Ther Clin Pract. 1996;3(5):26-31.
Sivaprakasam K, Rao K K, Anandan T, et al. Clinical evaluation of the effect of Siddha drugs on diabetes mellitus. J Res Ayurveda and Siddha. June. 1985;6(2):163-170.
Smith U, Holm G. Effect of a modified guar gum preparation on glucose and lipid levels in diabetics and healthy volunteers. Atherosclerosis. 1982;45(1):1-10. [pmid: 6297515].
Sivaprakasam K, Rao KK, Yasodha R, et al. Siddha remedy for diabetes mellitus. J Res Ayurveda and Siddha 1984 Mar, June, Sept, Dec;V(1, 2, 3 & 4):25–32.
Sodhi V. Ayurveda: The science of life and the mother of the healing arts. In: Pizzorno J and Murray M, editors. Textbook of natural medicine, Bastyr University. Seattle (WA); 1992.
Srivastava Y, Venkatakrishna-Bhatt H, Jhala C I, et al. Oral Gymnema sylvestre R.Br. leaf extracts inducing protracted longevity and hypoglycemia in alloxan diabetic rats: Review and experimental study. Int J Crude Drug Res. 1986;24:171-176.
Srivastava Y, Venkatakrishna-Bhat H, Verma Y, et al. Antidiabetic and adaptogenic properties of Momordica charantia extract: An experimental and clinic evaluation. Phytother Res. 1993;7(4):285-289.
Srividya N, Periwal S. Diuretic, hypotensive and hypoglycaemic effect of Phyllanthus amarus. Indian J Exp Biol. Nov. 1995;33(11):861-4. [pmid: 8786163].
Thorwald J. Science and secrets of early medicine. New York: Harcourt, Brace & World, Inc; 1963.
Udupa KN. The Ayurvedic system of medicine in India. Geneva: World Health Organization; 1977.
Udupa KN. Promotion of “health for all” by Ayurveda and yoga. Varanasi (India): The Tara Printing Works; 1985.
Vaishnav MM, Gupta KR. A new saponin from Coccinia indica roots. Fitoterapia 1995;LXVI(6):546–547.
Welihinda J, Karunanayake E H, Sheriff M H R. Effect of Momordica charantia on the glucose tolerance in maturity onset diabetes. J Ethnopharmacol. 1986;17:277-282. [pmid: 3807390].
Yoshikawa K, Kondo Y, Arihara S, et al. Antisweet natural products. IX. Structures of gymnemic acids XVBXVIII from Gymnema sylvestre. R Br V. Chem Pharm Bull (Tokyo). 1993;41(10):1730-1732.
Yoshikawa K, Nakagawa M, Yamamoto R, et al. Antisweet natural products. V. Structures of gymnemic acids VIIIBXII from Gymnema sylvestre R Br. Chem Pharm Bull (Tokyo). 1992;40(7):1779-1782.
Zafar R, Neerja. Momordica charantia — A review. Hamdard Medicus. 1991;34(3):49-61. [pmid: 11613982].
Zysk KG. Ayurveda. In: Micozzi M, editor. Fundamentals of complementary and alternative medicine. New York: Churchill Livingstone; 1996.