# References

Acharya R K, Upadhyay B N, Dwivedi L D. Dietary management in prameha. Ancient Sci Life. 1996;15(3):176-89.
Agrawal P, Rai V, Singh R B. Randomized placebo-controlled single-blind trial of holy basil leaves in patients with non-insulin-dependent diabetes mellitus. Int J Clin Pharmacol Ther. 1996;34:406-9. [pmid: 8880292].
Ajgaonkar S S. Herbal drugs in the treatment of diabetes: a review. Int Diabetes Fed Bull. 1979;24:10-17.
Alternative Med Rev. Gymnema sylvestre. 1999;4(1):46–47.
Khan Azad A K, Akhtar S, Mahtab H. Coccinia indica in the treatment of patients with diabetes mellitus. Bangladesh Med Res Counc Bull. Dec. 1979;5(2):60-6. [pmid: 399436].
Baghel MS. Researches in Ayurveda: A classified directory of all India P. G. and Ph.D. theses of Ayurveda. Jamnagar (India): MRIDU Ayurvedic Publications and Sales; 1997.
Bailey C J, Day C. Traditional plant medicines as treatments for diabetes. Diabetes Care. 1989;12(8):553-564. [pmid: 2673695].
Baskaran K, Ahamath B K, Shanmugasundaram K R, et al. Antidiabetic effect of a leaf extract from Gymnema sylvestrein non-insulin-dependent diabetes mellitus patients. J Ethnopharmacol. Oct. 1990;30(3):295-300. [pmid: 2259217].
Bhandari U, Grover J K. A reappraisal of clinical studies on the comparative influences of three indigenous plant drugs in diabetes mellitus. Hamdard Medicus. 1998;41(2):9-15.
Bharti M S, Singh R H. Constitutional study of patients of diabetes mellitus vis-à-vis Madhumeha. Ancient Sci Life. 1995;15(1):35-42.
Blumenthal M, Goldberg A, Brinkman J. Herbal medicine: Expanded German Commission E. Austin (TX): American Botanical Council; 2000, 130–133.
Bone K. Clinical applications of Ayurvedic and Chinese herbs: Monographs for the western practitioner. Warwick (Queensland, Australia): Phytotherapy Press; 1996.
Brahmchari H D, Augusti K T. Orally effective hypoglycemic principles from Coccinia indica. J Pharm Pharmacol. 1963;15:411-412. [pmid: 14014882].
Brala P M, Hagen R L. Effects of sweetness perception and caloric value of a preload on short term intake. Physiol Behav. 1983;30:1-9. [pmid: 6836034].
Chakravarthy B K, Gupta S, Gambhir S S, et al. Pancreatic beta-cell regeneration—A novel antidiabetic mechanism of Pterocarpus marsupiumRoxb. Indian J Pharmacol. 1980;12(2):123-127.
Chandola H M, Tripathi S N, Udupa K N. Hypoglycaemic response of C. tamala in patients of maturity onset (insulin independent) diabetes. J Res Ayurveda and Siddha. June. 1980a;1(2):275-2790.
Chandola H M, Tripathi S N, Udupa K N. Variations in the progression of maturity onset diabetes according to body constitution. Ancient Sci Life. 1994;13(3&4):293-301.
Chattopadhyay R R, Medda C, Das S, et al. Hypoglycemic and antihyperglycemic effect of Gymnema sylvestre leaf extract in rats. Fitoterapia. 1993;LXIV(5):450-4.
Chattopadhyay R R. Possible mechanism of antihyperglycemic effect of Gymnema sylvestre leaf extract. Part 1. Gen Pharmacol. 1998;31(3):495-6. [pmid: 9703226].
Chowdhary DP, Dua M, Bharti, et al. Hypoglycaemic effect of a coded formulation: Aysuh-82. J Res Ayurveda and Siddha 1998 July-Dec 31;XIX(3–4):107–115.
Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale (NJ): L. Erlbaum Associates; 1988.
Dash VB. Materia medica of Indo-Tibetan medicine. Delhi: MDIA Classics India Publications; 1987,10–11.
Frank R A, Mize S J S, Kennedy L M, et al. The effect of Gymnema sylvestre extracts on the sweetness of eight sweeteners. Chem Senses. 1992;17(5):461-479.
Gerson, S. Personal communication. 7 Nov 2000.
Goyal DK, Tiwari SK. Study on sadabahar (Vinca rosea Linn) in madhumeha (diabetes mellitus). J Res Ayurveda and Siddha 1999 Jan-June 30;XX(1–2):93–100.
Hellekant G, Hagstrom E C, Kasahara Y, et al. On the gustatory effects of miraculin and gymnemic acid in the monkey. Chem Senses and Flavor. 1974;1:137-145.
Hii S C T, Howell S L. Effects of epicatichin on rat islets of Langerhans. Diabetes. 1984;33:291-296. [pmid: 6365662].
Hossain M Z, Shibib B A, Rahman R. Hypoglycemic effects of Coccinia indica: Inhibition of key gluconeogenic enzyme, glucose-6-phosphatase. Indian J Exp Biol. 1991;30:418-420. [pmid: 1334043].
Imoto T, Miyasaka A, Ishima R, et al. A novel peptide isolated from the leaves of Gymnema sylvestre. Part 1. Characterization and its suppressive effect on the neural responses to sweet taste stimuli in the rat. Comp Biochem Physiol. 1991;100A(2):309-314.
Indian Council for Medical Research (ICMR). Role of fenugreek seeds in diabetes mellitus. ICMR Bulletin 1987;17(9):79–93.
Indian Council for Medical Research, ICMR Collaborating Centres, Central Biostatistical Monitoring Unit, Chennai & Central Technical Co-ordinating Unit, ICMR New Delhi. Flexible dose open trial of Vijayasar in cases of newly-diagnosed non-insulin-dependent diabetes mellitus. Indian J Med Res 1998 July;108:24–29.
Ivorra M D, Paya M, Villar A. A review of natural products and plants as potential antidiabetic drugs. J Ethnopharmacol. 1989;27:243-275. [pmid: 2693840].
Jadad A R, Moor A R, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jain S C, Agrawal M, Sharma R A. The genus Trigonella—Phytochemistry and biology. Ancient Sci Life. 1996;XVI:108-117.
Jain SK, DeFilipps RA. Medicinal plants of India. Algonac (MI): Reference Publications, Inc.; 1991.
Jellin JM, Batz F, Hitchens K. Pharmacist's letter/prescriber's letter Natural Medicines Comprehensive Database. Stockton (CA): Therapeutic Research Facility; 1999.
Kamble SM, Jyotishi GS, Kamalakar PL, et al. Efficacy of Coccinia indica W. & A. in diabetes mellitus. J Res Ayurveda and Siddha 1996 Jan-June 30;XVII(1–2):77–84.
Kamble S M, Kamlakar P L, Vaidya S, et al. Influence of Coccinia indica on certain enzymes in glycolytic and lipolytic pathway in human diabetes. Indian J Med Sci. Apr. 1998;52(4):143-146. [pmid: 9770877].
Kamei K, Takano R, Miyasaka A, et al. Amino acid sequences of sweet-taste-suppressing peptide (gurmarin) from the leaves of Gymnema sylvestre. J Biochem (Tokyo). 1992;111:109-112. [pmid: 1607357].
Kapoor LD. CRC handbook of Ayurvedic medicinal plants. Boca Raton (FL): CRC Press, Inc.; 1990.
Kar C A, Upadhyay B N, Ojha D. Prognosis of prameha on the basis of insulin level. Ancient Sci Life. April. 1997;XVI:277-283.
Khajuria S, Thomas J. Traditional Indian beliefs about the dietary management of diabetes - An exploratory study of the implications for the management of Gujarati diabetics in Britain. J Hum Nutr Diet. 1992;5(5):311-321.
Kohli KR, Singh RH. A clinical trial of jambu (Eugenia jambolana) in non-insulin dependant diabetes mellitus. J Res Ayurveda and Siddha 1993 Sept-Dec 31;XIV(304):89–97.
Kumar N, Kumar A, Sharma ML. Clinical evaluation of single and herbo-mineral compound drugs in the management of madhumeha. J Res Ayurveda and Siddha 1999 Jan-June 30;XX(1–2):1–9.
Kuppurajan K, Seshadri C, Revathi R, et al. Hypoglycaemic effect of Coccinia indica in diabetes mellitus. Nagarjun. Jan. 1986;29(5):1-4.
Kuppu Rajan K, Srivatsa A, Krishnaswami C V, et al. Hypoglycemic and hypotriglyceridemic effects of methika churna (fenugreek). Antiseptic. 1998;95(3):78-79.
Lawrence Review of Natural Products. Fenugreek. 1996; July:1–3.
Lawrence Review of Natural Products. Gymnema. 1993; Aug:1–2.
Lewis WH, Elvin-Lewis MPF. Medical botany: Plants affecting man's health. New York: Wiley; 1977.
Lodha R, Bagga A. Traditional Indian systems of medicine. Ann Acad Med Singapore. June. 2000;29(1):37-41. [pmid: 10748962].
Maji D, Singh A K. Clinical trial of D-400, a herbomineral preparation in diabetes mellitus. J Diabetic Assoc India. 1995;35(1):1-4.
Manickam M, Ramanathan M, Jahromi M A, et al. Antihyperglycemic activity of phenolics from Pterocarpus marsupium. J Natural Prod. 1997;60(6):609-610.
Marles R J, Farnsworth N R. Antidiabetic plants and their active constitutents. Phytomedicine. 1995;2(2):137-189.
Mishra L, Singh B, Dagenais S. Ayurveda: A historical perspective and principles of the traditional healthcare system in India. Altern Ther Health Med. Mar. 2001b;7:36-42. [pmid: 11253415].
Mishra L, Singh B, Dagenais S. Healthcare and disease management in Ayurveda. Altern Ther Health Med. Mar. 2001a;7:44-50. [pmid: 11253416].
Moher D, Pham B, Jones A, et al. Does quality of reports of randomized trials affect the estimates of intervention efficacy reported in meta-analysis?. Lancet. 1998;352:609-13. [pmid: 9746022].
Nadkarni AK, Nadkarni KM. Indian materia medica. 3rd ed. Bombay: Popular Prakashan; 1976.
Nagaraju N, Prasad M, Gopalakrishna G, et al. Blood sugar lowering effect of Pterocarpus santalinus (red sandal) wood extract in different rat models. Int J Pharmacognosy. 1991;29(2):141-144.
Pandey VN, Rajagopalan SS, Chowdhary DP. An effective Ayurvedic hypoglycemic formulation. J Res Ayurveda and Siddha 1995 Jan-June 30;XVI(1–2):1–14.
Persaud S J, Al-Majed H, Raman A, et al. Gymnema sylvestre stimulates insulin release in vitro by increased membrane permeability. J Endocrinol. 1999;163(2):207-212. [pmid: 10556769].
Prakash A O, Mathur S, Mathur R. Effect of feeding Gymnema sylvestre leaves on blood glucose in beryllium nitrate treated rats. J Ethnopharmacol. 1986;18:143-146. [pmid: 3560992].
Raman A, Lau C. Anti-diabetic properties and phytochemistry of Momordica charantia (curcubitacea). Phytomedicine. 1996;2(4):349-62.
Raman A, Skett P. Traditional remedies and diabetes treatment. In: Prendergast HDV, Etkin NL, Harris DR, Houghton PJ, editors. Plants for food and medicine. London: Royal Botanic Gardens, Kew 1998; 361–372.
Shah V. Diabetes mellitus in Indian medicine. Varansi (India): Chaukhambha Orientalia; 1995.
Shankar R, Singhal RK. Clinical assessment of the effects of sandana (sandal) podi-a in the treatment of diabetes mellitus (neerazhiv). J Res Ayurveda and Siddha 1994 Sept-Dec 31;XV(3–4):89–97.
Shankar R, Singhal RK. Clinical studies of the effect of abraga (mica) chendooram in the treatment of diabetes mellitus (neerazhivu). J Res Ayurveda and Siddha 1995 July-Dec 31;XVI(3–4):108–117.
Shanmugasundaram E R, Gopinath K L, Shanmugasundaram K R, et al. Possible regeneration of the islets of Langerhans in streptozotocin-diabetic rats given Gymnema sylvestre leaf extracts. J Ethnopharmacol. 1990a;30:265-279. [pmid: 2259215].
Shanmugasundaram E R, Rajeswari G, Baskaran K, et al. Use of Gymnema sylvestre leaf extract in the control of blood glucose in insulin-dependent diabetes mellitus. J Ethnopharmacol. Oct. 1990b;30(3):281-94. [pmid: 2259216].
Shanmugasundaram E R, Venkatasubrahmanyam M, Vijendran N, et al. Effect of an isolate from Gymnema sylvestre, R.Br. in the control of diabetes mellitus and the associated pathological changes. Ancient Sci Life. 1988;VII(3 and 4):183-194.
Shanmugasundaram K R, Panneerselvam C, Samudram P, et al. Enzyme changes and glucose utilisation in diabetic rabbits: The effect of Gymnema sylvestre, R Br. J Ethnopharmacol. Mar. 1983;7(2):205-234. [pmid: 6865451].
Shanmugasundaram K R, Panneerselvam C, Samudram P, et al. The insulinotropic activity of Gymnema sylvestre, R.Br. An Indian medical herb used in controlling diabetes mellitus. Pharm Res Communications. May. 1981;13(5):475-486.
Sharma R D, Sarkar A, Hazra D K, et al. Use of fenugreek seed powder in the management of non-insulin dependent diabetes mellitus. Nutr Res. 1996a;16:1331-1339.
Shimizu K, Iino A, Nakajima J, et al. Suppression of glucose absorption by some fractions extracted by Gymnema sylvestre leaves. J Vet Med Sci. 1997;59(4):245-251. [pmid: 9152931].
Singh N, Singh S P, Vrat S, et al. A study on the anti-diabetic activity of Coccinia indica in dogs. Indian J Med Sci. 1985;39:27-29. [pmid: 3997215].
Sircar A R, Ahuja R C, Natu S M, et al. Hypoglycemic, hypolipidemic and general beneficial effects of an herbal mixture MA-471. Altern Ther Clin Pract. 1996;3(5):26-31.
Sivaprakasam K, Rao KK, Yasodha R, et al. Siddha remedy for diabetes mellitus. J Res Ayurveda and Siddha 1984 Mar, June, Sept, Dec;V(1, 2, 3 & 4):25–32.
Srivastava Y, Venkatakrishna-Bhatt H, Jhala C I, et al. Oral Gymnema sylvestre R.Br. leaf extracts inducing protracted longevity and hypoglycemia in alloxan diabetic rats: Review and experimental study. Int J Crude Drug Res. 1986;24:171-176.
Vaishnav M M, Gupta K R. A new saponin from Coccinia indica roots. Fitoterapia. 1995;LXVI(6):546-547.
Yoshikawa K, Kondo Y, Arihara S, et al. Antisweet natural products. IX. Structures of gymnemic acids XVBXVIII from Gymnema sylvestre. R Br V. Chem Pharm Bull (Tokyo). 1993;41(10):1730-1732.
Yoshikawa K, Nakagawa M, Yamamoto R, et al. Antisweet natural products. V. Structures of gymnemic acids VIIIBXII from Gymnema sylvestre R Br. Chem Pharm Bull (Tokyo). 1992;40(7):1779-1782.
Zafar R, Neerja. Momordica charantia — A review. Hamdard Medicus. 1991;34(3):49-61. [pmid: 11613982].