# Future Research

Our review has suggested a number of interesting avenues for future research:

- Basic scientific study of Ayurveda has not been adequately pursued. Field studies to observe how Ayurvedic therapeutic systems are used in real-life clinical practice would generate much useful data, which could suggest further areas for research.
- Studies could be designed to test the effects of other Ayurvedic modalities, such as yoga, on diabetic outcomes.
- Greater efforts to correlate Ayurvedic diagnostic categories with either Western diagnostic or physiologic measures would be useful. This work was begun in the studies that examined the various doshas of diabetic patients and attempted to correlate them with physical characteristics or laboratory values (e.g., weight or glucose). These studies should be expanded, but they should be conducted with greater rigor. All subjective assessments should have at least two independent observers who reconcile their observations. Random or representative samples of diabetic and non-diabetic patients should be enrolled.
- The prospective accuracy of the diagnosis of madhumeha to identify diabetic patients, both those in good and poor control, could also be assessed. A comparison of the distribution of clinically useful Ayurvedic parameters in the diabetic population versus the general population would shed light on the specificity of the Ayurvedic diagnosis for madhumeha.

The Ayurvedic literature reported mainly studies of single herbs; however, herbs are usually given in combination in clinical Ayurvedic practice. Formulas can include minerals and metals in addition to multiple plants. Ayurvedic practitioners assert that the sum of a formula is more potent than the constituents taken individually and, further, that the mineral and metal components boost the formula's potency. This would be an interesting premise to test and could be explored using investigative techniques below the level of an RCT.

A significant amount of clinical research exists for several herbs (e.g., Gymnema, and fenugreek), and this work should be replicated using better investigative techniques. The paucity of RCT and CCT study designs makes it difficult to assess the efficacy of Ayurvedic herbs for diabetes. In general, future clinical studies need to be better designed than those reported in the literature and evaluated here. New studies would need to enroll an adequate number of subjects to demonstrate at least moderate clinical effects. Interventions should be compared to placebo preparations, and care should be taken to construct placebos that cannot be distinguished from the trial drug based on taste, color, or smell. This is sometimes a difficult task with herbal preparations that are not encapsulated; however, it is not insurmountable. Clinical studies using Ayurvedic therapies for diabetes would need to be better reported. The methods used for patient selection and assignment to arms need to be better described, and the reporting of results should follow good statistical practice. In addition, studies of sufficient length to determine a relevant clinical effect need to be conducted. Hemoglobin A_1c_, the most valid intermediate clinical measure of glucose control, requires a study of at least 3 months.

Well-planned trials would integrate Ayurvedic diagnosis and assessment into their design. Those therapies that are commonly used in Ayurveda, such as diet, yoga, or special purification routines, should be controlled for when recruiting and assessing patients. It is also critical to track results that would be of interest to the traditional practitioners who developed the modalities being assessed. Presumably, these therapies would be most effective for these type of outcomes. In the case of diabetes, it is likely that the traditional practitioner would focus on symptom reduction and a decrease of sweetness in the urine as clinically relevant outcomes, as well as on changes in dosha derangements.

In future state-of-the-art Ayurvedic clinical methods, studies should include more sophisticated diabetic research methods. Few of the studies we reviewed recorded weight or body mass index or looked to see what effect, if any, Ayurvedic herbs had on obesity. The herbs' peripheral effects on insulin action in muscle, the liver, or the intestine could be investigated with both in-vitro models and patients.

In summary, this review has demonstrated that a useful body of data exists on the use of Ayurvedic modalities, principally herbal, for the treatment of diabetes (madhumehaand that further investigation into the most promising areas is indicated.