# Conclusions

This evidence report assessed the distribution of published studies of Ayurvedic medicine in general and performed a more detailed review of Ayurvedic therapy for diabetes mellitus.

With regard to Ayurvedic therapies in general, we identified a large body of literature and were able to make the following observations:

- The most common conditions or body systems for which studies of Ayurvedic therapies have been published are:
  - Diabetes mellitus
  - Infectious diseases
  - Liver/hepatitis
  - Hypercholesterolemia
  - Central nervous system disorders (dementia/depression)
  - Cardiovascular diseases
- The Ayurvedic therapy most commonly cited in the literature is herbal therapy. Very few studies were found on any other Ayurvedic modalities.
- Studies of single herbs are reported much more frequently in the literature than investigations of herbal formulas or combinations. Sixty-seven percent of the studies were for single-herb interventions.
- No studies were found that tested Ayurveda as a whole system or that tested multiple modalities for the same disease state at the same time.
- A significant body of literature in English exists in India; it can be identified, and a large portion of the studies can be obtained with effort. However, even after extensive efforts, a handful of English-language studies could not be found. Studies in non-English languages in India were not reviewed.

Our review supports the following conclusions regarding Ayurvedic therapy for diabetes:

- There is great heterogeneity in the available literature on Ayurvedic treatment for diabetes, despite the fact that the overwhelming majority of studies test herbal therapy. Heterogeneity exists in the herbs and formulas tested (more than 44 different interventions identified) and in the method of their preparation.
- We observed significant methodological shortcomings, specifically:
  - There were few RCTs and CCTs.
  - Studies in general were underpowered to determine even large effect sizes. Many studies had an extremely small number of subjects (fewer than 10).
  - In a number of studies, appropriate statistical methods were not used in reporting the results.
  - The majority of the studies tested NIDDM (type 2) patients only. Therefore, no definitive conclusion can be drawn on the effect of these therapies on IDDM (type 1).
- Even with these limitations, several herbs or herbal formulas have sufficient data to warrant further study:
  - The single best quality RCT demonstrated beneficial results for Coccinia indica. For other studies of Coccinia indica, however, results were not consistent but generally reported beneficial results.
  - A single trial of holy basil reported a beneficial outcome on the control of fasting blood glucose only.
  - Studies using fenugreek generally reported beneficial results for control of cholesterol and, to a lesser degree, for improved blood glucose control.
  - Gymnema sylvestre was used in a number of studies, again with generally beneficial results. In particular, a standardized extract of Gymnema (GS4) showed improved glucose control in trials. Gymnema was also a constituent in two of the formulas that showed beneficial results: D-400 and Ayush-82.
  - Two Ayurvedic formulas, D-400 and Ayush-82, were used in a number of studies that showed promising results.

Table 28 summarizes our results for four specific herbs and two formulas with the strongest evidence for benefit.

Table 28. Results summary of Ayurvedic interventions for diabetes mellitus

Intervention | # studies (# arms) | RCTs | CCTs | Other study designs | Studies favoring treatment | Studies not favoring treatment
Gymnema (single herb) | 7 (10) | 0 | 3 | 4 | 6 | 1
Gymnema (formula) | 11 (15) | 0 | 4 | 7 | 11
Coccinia Indica | 4 (5) | 1 | 1 | 2 | 3 | 1
Fenugreek (single herb) | 10 (15) | 0 | 0 | 10 | 9 | 1 study measured only cholesterol
Fenugreek (formula) | 2 (3) | 0 | 0 | 2 | 2
Holy basil | 1 | 1 | 0 | 0 | 1
D-400 | 2 | 0 | 1 | 1 | 2
Ayush-82 | 5 | 0 | 0 | 5 | 5

RCT=randomized controlled trial; CCT=controlled clinical trial

- Evidence of effectiveness of several other herbs exists, although it is not as extensive. Three beneficial studies were found for C. tamala, one CCT and two case series. Three noncontrolled studies of Eugenia jambolana were found, one of which reported mixed results but two of which reported favorable results. Five noncontrolled studies of Momordica charantia, including two that tested immediate hypoglycemic effects, were found: four reported beneficial results and one demonstrated mixed results.
- There were some qualitative differences between the Indian studies published in the West and the Western studies, despite the fact that most of the studies were done in India.
  - There were more RCTs and CCTs in the Western literature and more case series in the Indian literature. This may reflect a publication bias in the Western literature for controlled trials or a willingness in India to publish data of a more observational or preliminary nature.
  - Ayurvedic terms and diagnostic criteria were significantly present only in the Indian literature. However, even though some of the Indian studies included Ayurvedic terms, these studies focused on Western diagnostic criteria and outcomes.
- No serious adverse events were reported in the studies from either India or the West. This observation is limited by the fact that adverse effects were not always specifically addressed and thus may have been underreported.

## Limitations of the Review

A number of factors prevent drawing any stronger conclusions from the data other than the ones presented above.

- Our searches showed that the Ayurvedic literature emphasizes botanical therapies. However, the structure of our search may have exaggerated this emphasis. Therefore, no conclusions can be drawn about the use of Ayurveda as a whole system for the treatment of diabetes.
- Articles without abstracts were excluded from the initial review by default. In addition, it was difficult to accurately complete the screening form based on titles alone, and the number of titles was too large to order all of the articles. It is possible that the inclusion of all of these articles might have changed the frequency of disease states in the initial review and, hence, the choice of our topic for in-depth review.
- Although extensive efforts were made to obtain the relevant Indian literature, studies not published in English were not included, and a handful of studies identified in India could not be retrieved. This means that there is information that was not included in the review.
- There were significant methodological difficulties with the literature analyzed. In general, random assignment to treatment was used infrequently; comparison arms were not included; and many of the studies had insufficient subjects to demonstrate effect sizes other than very large ones. In addition, we could not calculate a common statistical measure in all studies. Thus, we were limited in the comparisons we could make between different therapeutic interventions, and we had no way to check for publication bias in either the Western or Indian literature.
- A number of the studies tested immediate or very rapid effects of the herbs used in the intervention. Although this might be interesting to elucidate the mechanism of action of the herb, it did not replicate normal clinical practice, and it limited our ability to generalize based on these data.
- All of the studies that we identified and analyzed were not of equal methodological quality. In order to avoid giving all studies equal weight (and perhaps thereby giving undue weight to studies of poorer quality), we tried to emphasize studies of better quality by subjecting them to further analysis.