# Results

## Description of the Evidence

Fifty-four articles reported on the results of 62 studies in diabetes during the search and review process for this evidence report, and they were then reviewed in depth. Thirty-five studies came from the Western literature, and 27 came from the Indian literature. The designs of the 62 studies were varied. There were 7 randomized controlled trials and 10 controlled clinical trials. There were 38 case series, the most frequently used clinical design, and 7 cohort studies.

The 62 studies discussed in this report are grouped and presented in Evidence Tables 1 and 2 or in Appendix L based on study design and therapeutic intervention.

Evidence Table 1 summarizes the characteristics of those RCTs and CCTs that had nonherbal comparison arm(s) and met the following criteria: duration of at least 30 days, at least 10 subjects, measurements of blood sugar and/or hemoglobin A_1C_ before and after herbal treatment. Both of the RCTs were reported in the Western literature. In addition, all of these studies were of sufficient quality to allow further analysis of effect size as described in Chapter 2, “Methodology.” The results of this analysis are displayed in Figure 1, which follows discussion of the individual studies included in Evidence Table 1.

Figure 1. Difference of Differences for RCTs and CCTs

Evidence Table 2 summarizes the characteristics of all studies that had pre/post comparison data available and also met the criteria outlined above. All studies that focused on single herbs are discussed first, followed by studies using formulas or combinations of herbs. Additional effect size analysis was conducted on these studies as described in Chapter 2. Analysis of the differences between pre-treatment and post-treatment blood glucose levels (fasting, post-prandial, and hemoglobin A_1c_), were calculated and the results are displayed in Figure 2, which follows discussion of the individual studies included in Evidence Table 2.

Figure 2. Pre/Post Comparison Group

Finally, all studies not meeting the criteria outlined earlier for inclusion in Evidence Tables 1 or 2 are presented in Appendix L 6. This group of miscellaneous studies is highly heterogeneous. Generally, they were excluded from Evidence Tables 1 and 2 because the duration of the study was too short (not at least 30 days); the number of patients studied was too small (n < 10); or the results reported did not include the values we had identified for analysis (fasting blood sugar, hemoglobin A_1c_, or post-prandial blood sugar).

See “Characteristics of Studies Not Included in Further Analysis” in Appendix L for a summary of the characteristics of these studies.

In terms of interventions, 45 unique herbs or herbal formulas were used 142 times in the 62 studies for which we did detailed analysis. (A study could have more than one intervention; thus the total number of interventions exceeded the number of studies). The two most commonly tested single herbs were Gymnema sylvestre (used 16 times in 12 studies) and fenugreek (used 18 times in 11 studies). The Ayurvedic formulas D-400 (used seven times in four studies) and Ayush-82 (used six times in five studies) were the two most commonly tested herbal formulas. These four interventions plus guar gum and Eugenia jambolana accounted for 50 percent of all the herbal interventions tested. Mineral substances were added to herbal formulas only six times. Diet was the focus of two studies but was used as an intervention or co-intervention 9 and 35 times, respectively.

## Quality of the Evidence

Only the RCTs and CCTs were given a Jadad score, which rates studies on a 0 to 5 scale (Jadad, Moor, Carroll, et al., 1996). A score is based on the answer to three questions: Was the study randomized? Was the study described as double blind? Was there a description of withdrawals and dropouts? One point is awarded for each “yes” answer, and no points are given for a “no” answer. An additional point is given if the randomization method was described and was appropriate. A point is deducted if the method is described but is not appropriate. In response to the second question, a point is awarded if the method of blinding is appropriate and described, and one point is deducted if the described method is inappropriate. Given the nature of some of the interventions used in Ayurvedic medicine, a true double-blind study would be difficult to perform, and the maximum Jadad score expected would then be 3 or 4. Empirical evidence has shown that studies scoring 2 or less report exaggerated results compared with studies scoring 3 or more (Moher, Pham, Jones, et al., 1998). Studies with a Jadad score of 3 or more are referred to as “high” quality, and studies scoring 2 or less are referred to as “poor” quality.

Of the seven RCT studies, four received a Jadad score of 1, two studies scored a 2, and only one study received a 4 on this scale. This is the only high quality study in our analysis. Seven of the CCT studies had a Jadad score of 0, and the remaining three studies scored only 1.

A methodological problem common to many of the studies was lack of statistical power—32 arms or studies had fewer than 10 subjects. This was especially true of the studies in Appendix L. Cohen (1988) defines an effect size as the absolute value of the difference in the treatment and control group means divided by the standard deviation. He further defines a “small” effect size as 0.2, a “medium” effect size as 0.5, and a “large” effect size as 0.8. Therefore, to achieve 80 percent power to detect a small effect size at a level of significance of p<0.05, at least 393 subjects would be needed in both treatment and control groups. To detect a medium effect size, 63 patients would be required in each group, and to detect a large effect size, 25 patients would be required. None of our studies had sufficient numbers to detect a small effect size, and most would not be able to detect even a medium effect size. Thus, the studies that failed to demonstrate an effect of herbal therapy could have been either truly ineffective or underpowered. The majority of the studies did show statistically significant results. Given the preceding discussion, we can postulate that either the effect sizes were large for these studies, the lack of random design exaggerated the beneficial effects of the interventions, or there exists a publication bias for studies reporting a beneficial effect.

## Synthesis of the Evidence

### Controlled Trials With Nonherbal Comparison Arm(s)

The seven trials that met the inclusion criteria (see “Quality of the Evidence,” above) were either RCTs (2) or CCTs (5); these studies are summarized in Evidence Table 1. All of them tested herbs as single agents, not in formulas or in combinations. Detailed descriptions of these studies follow.

#### Randomized Controlled Trials

Azad Khan, Akhtar, and Mahtab (1979) performed a randomized controlled trial to assess the hypoglycemic properties of a preparation of the herb Coccinia indica on uncontrolled and untreated type 2 diabetic patients. Thirty-eight patients with type 2 diabetes who were attending the outpatient department of the Bangladesh Institute of Research and Rehabilitation in Diabetes in Dhaka, Bangladesh, were recruited for the study. Only uncontrolled or newly diagnosed patients were enlisted. Patients who had evidence of renal disease, hepatic disease, or neuropathy or who had ketones in their urine were excluded. There were six dropouts from the study, and 32 (84 percent) patients completed the study. The patients were randomly allotted to receive either a plant preparation (Arm II, n=16, 23 percent female, age 51 ± 10 years) or placebo (Arm I, n= 16, 14 percent female, age 44 ± 5 years). Four of the dropouts were from Arm I, and two were from Arm II. The patients were reported to be similar with respect to diagnosis and therapy. No mention of socioeconomic status was made. Arm I patients received placebo twice a day for 6 weeks. The intervention consisted of a freeze-dried powder of crushed leaves of Coccinia indica, given in a dose of 900 mg twice a day for 6 weeks for Arm II.

Study results are shown in Table 13. Of the 16 patients in receiving Coccinia indica, 10 patients showed a marked improvement in the glucose tolerance tests to values closer to normal, while none in the placebo arm showed marked improvement. Limitations of this trial are its short duration^7^ and the small number of patients. The Jadad score for the trial was 4.

Short duration is defined as less than 12 weeks.

Table 13. Study results for Azad Khan, Akhtar, and Mahtab, 1979

| Arm I (placebo) | | Arm II (Coccinia)
Variable | Pre-treatment | Post-treatment | Pre-treatment | Post-treatment
Fasting blood sugar (mg/dl) | 195.5 | 181.3 | 178.8 | 122.1 (p<0.01)
1-hour post-prandial blood sugar (mg/dl) | 281.1 | 267.6 | 268.1 | 224.9 (p<0.05)
2-hour post-prandial blood sugar (mg/dl) | 255.1 | 252.0 | 245.4 | 186.9 (p<0.01)

Agrawal, Rai, and Singh (1996) reported the results of a randomized, placebo controlled crossover trial of the effects of a leaf extract of holy basil (Ocimum sanctum) on type 2 diabetic patients. The patients (n=62) were recruited from community advertisements in Kanpur, India, and through visits to the offices of local dieticians. The diagnosis of diabetes was made through a glucose tolerance test. Patients were excluded from the trial if they used holy basil leaves frequently; had a blood urea level > 40 mg/dl; had diarrhea or dysentery; had cancer; had 2-hour PPBS > 350 mg/dl; did not like to eat holy basil; had type 1 diabetes; or did not have diabetes. Of the 62 patients selected, 22 were excluded. The remaining patients (n=40, 37.5 percent female, age 41–65 years) were entered into the trial. The mean duration of diabetes was 8.6 years (1.5–13 years), body weight ranged from 55–75 kg, mean systolic blood pressure was 137 mm Hg (122–170 mm Hg) and mean diastolic blood pressure was 89 mm Hg (80–110 mm Hg).

The crossover design was performed as follows. All subjects had a 5-day run-in period during which they all consumed a tea made from holy basil leaves. This was followed by an 8-week experimental period. The patients were randomly assigned to one of two arms. The first arm drank the holy basil leaf tea for 4 weeks followed by placebo leaves for 4 weeks. The second arm had the placebo leaves first, followed by the holy basil leaf tea. All the patients were advised not to change their physical activity and diets and to stop taking their oral hypoglycemic agents 7 days prior to the start of the trial. The active medication was dispensed in a sachet containing dried leaf powder made from 2.5 g of fresh leaves of holy basil. The placebo was identical except that it contained spinach leaf powder. Subjects were instructed to mix the contents of the sachet in 200 ml of water and to drink the mixture on an empty stomach in the morning. Compliance was monitored by counting the number of unused sachets returned by the patients at each visit.

Study results (Table 14) and laboratory data at the end of each treatment period (Table 15) are summarized below.

Table 14. Study results for Agrawal, Rai, and Singh, 1996

Variable | Holy basil treatment first | | | Placebo treatment first
| Baseline | First 4 weeks | Second 4 weeks | Baseline | First 4 weeks | Second 4 weeks
Fasting blood sugar (mg/dl) | 134.5 | 99.7 (p<0.1) | 115.6 | 132.4 | 123.2 | 97.2 (p<0.1)
Post-prandial blood sugar (mg/dl) | 223.9 | 204.0 (p<0.1) | 217.1 | 221.6 | 215.1 | 197.1 (p<0.1)
Total cholesterol (mg/dl) | 238.2 | 221.5 | 236.0 | 233.0 | 236.2 | 220.1

Table 15. Laboratory data at end of each treatment period, Agrawal, Rai, and Singh, 1996

Variable | Placebo treatment | Holy basil treatment | Difference in effects of treatment | Change (%)
Fasting blood glucose (mg/dl) | 119.4 | 98.6 | -31.4 to -11.2 (p<0.001) | -17.6
Post-prandial blood sugar (mg/dl) | 216.1 | 200.5 | -27.0 to -5.6 (p<0.02) | -7.3
Total cholesterol (mg/dl) | 236.1 | 220.8 | -26.5 to 8.7 (p<0.02) | -6.5

The authors concluded that holy basil leaf powder caused significant reduction in the level of fasting blood sugar and post-prandial blood sugar, and a moderate reduction in cholesterol. They suggested that holy basil leaf powder may be a useful adjunct to other treatments for type 2 diabetes. The small numbers of patients and the fact that the patients were not blinded to the sequence of treatment given (holy basil powder has a distinctive taste and does not taste like spinach powder) are the significant drawbacks of the study as well as its short duration. The Jadad score for this trial is 1.

#### Controlled Clinical Trials

Chandola, Tripathi, and Udupa (1980a) performed a series of three studies with type 2 diabetic patients to study the hypoglycemic effects of Cinnamonum tamala. Only one study is a CCT, but all three studies are discussed together here.

In the first study, a group of type 2 diabetic patients (Arm I, n=32, 5 percent female, ages 35–70) were recruited from the outpatient departments of the Institute of Medical Sciences, Varanasi, India. Another group of type 2 diabetic patients (Arm II, n=8, 0 percent females, ages 39–50) served as controls. The socioeconomic characteristics of the patients were not noted. The authors did not report if the two arms of patients were statistically equivalent on important prognostic variables at the start of the trial. The intervention consisted of leaves of Cinnamonum tamala (tejpatra) that were dried, pulverized, and filtered through a fine mesh. The powder was packed into 100 g packets. The patients in Arm I were given 2 heaped teaspoons of the powder four times a day before meals and tea for a total of 1 month. All patients were advised to follow an 1,800-calorie diet with restriction of sugar, potato, and rice. The patients in Arm II were only instructed to follow the above diet with no other medications. Fasting blood sugars were assessed in both arms of patients before the trial and at the end of 1 month.

The results of the first study are as follows: In Arm I, mean fasting blood sugar improved from 153.44 mg/dl to 112.65 mg/dl (p<0.001) at the end of 1 month. In Arm II, the mean fasting blood sugar increased from 156.37 mg/dl to 164.12 mg/dl (p<0.01) at the end of 1 month. The Jadad score for this CCT was 0.

The second study was a case series with pre/post data available in which a series of type 2 diabetic patients (n=25, 4 percent female, ages 36–70), diagnosed by glucose tolerance tests, were recruited from the outpatient departments of the Institute of Medical Sciences, Varanasi, India. The patients were given Cinnamonum tamala for 1 month. It was prepared in a similar manner and dose as described for the first study. Glucose tolerance tests were done at the start and at the end of 1 month. The results for the second study are reported in Table 16.

Table 16. Study results of Chandola, Tripathi, and Udupa, 1980a, second study

| Fasting blood sugar (mg/dl) | 1-hour post-prandial blood sugar (mg/dl) | 2-hour post-prandial blood sugar (mg/dl)
Pre-trial | 144.84 | 258.64 | 236.15
Post-trial | 103.51 (p<0.001) | 206.89 (p<0.001) | 170.59 (p<0.001)

In the third study, another case series with pre/post data available, the immediate hypoglycemic effect of Cinnamonum tamala was evaluated in a series of seven patients (0 percent female, ages 35–68 years). No other demographic characteristics of the patients were reported. All patients had blood drawn for a fasting blood sugar after which they were given 20 g of Cinnamonum tamala powder. Blood sugar levels were assessed at 1 hour and 2 hours after administration of the herb. The authors reported that mean blood sugar decreased from 166.28 mg/dl to 145.57 mg/dl at 1 hour (p<0.02) and to 122.28 (p<0.01) mg/dl at 2 hours.

Based on these three studies, the authors concluded that Cinnamonum tamala has a definite hypoglycemic effect and its role in the management of diabetes is established. However, the short duration of all the studies, the lack of randomized control arms, and the small numbers of patients prevent definitive conclusions being drawn.

Kamble, Jyotishi, Kamalakar, et al. (1996) studied the effect of fresh leaves of Coccinia indica on blood sugar levels and on hyperlipidemia in non-insulin-dependent diabetes mellitus (NIDDM, type 2) patients at an Ayurvedic clinic in Nagpur, India. Patients were classified into four arms: a healthy comparison arm (Arm I, 15 patients); a NIDDM comparison arm (Arm II, 30 patients); NIDDM patients treated with Coccinia (Arm III, 25 patients); and a NIDDM arm treated with Chlorpropamide (Arm IV, 15 patients). Patients received a glucose tolerance test and were evaluated for existing diabetic complications. Patients ranged in age from 21 to 55 years; no other demographic information was provided. Patients were given the Coccinia (decocted from fresh leaves, dried into a paste, and made into a 3 g tablet) twice a day for 12 weeks.

For patients in Arm III, the study showed a statistically significant reduction in mean fasting blood sugar, from 160 to 110 mg/dl (p<0.001), and a significant decrease in blood sugar levels after glucose tolerance tests: the 2-hour level dropped from 308 mg/dl to 142 mg/dl (p<0.001). These results were roughly equivalent to those found in the Chlorpropamide arm. Additionally, after 12 weeks of treatment, the Coccinia treated patients showed significant reductions in levels of cholesterol (p<0.001), phospholipid (p<0.05), triglyceride (p<0.001), and free fatty acid (p<0.001) compared to untreated diabetics. These levels approach those of the healthy comparison arm. Within the treatment group, no pre/post data are reported for the changes in the lipid levels. No adverse effects were reported from this trial.

The researchers concluded that Coccinia indica significantly reduces hyperlipidemia and serum glucose levels in NIDDM (type 2) patients. The authors postulate that the hypocholesterolemic effect may be due to the presence of beta-sito-sterol containing an ethyl group that may interfere with the absorption of cholesterol in the gut. They also postulate that the hypoglycemic effect, which was similar to that of Chlorpropamide, may be a result of the anabolic insulin-like properties of the plant. The authors' conclusions would be further supported if the study had been done in a randomized and blinded manner. The Jadad score was 0.

Kohli and Singh (1993) studied the effects of Jamun beej (Eugenia jambolana) on fasting blood sugar, glucose tolerance test, and symptomatic relief of symptoms associated with diabetes. Thirty patients identified from the outpatient unit of the Sunderlal Hospital in Varanasi, India, who had NIDDM confirmed by glucose tolerance test, were given the herb. Seeds of Eugenia jambolana were obtained from the local market and crushed into a fine powder. The patients were instructed to take 4 g three times a day for 3 months. No dietary restrictions were included in the study. A second arm of six patients with confirmed NIDDM was given Chlorpropamide (250 mg per day). No demographic information was provided on these patients. The Jadad total is 1.

Results for the herb-treated arm are shown in Table 17. The study showed a statistically significant reduction in mean fasting blood sugar of 51.86 mg/dl at 2 months (p<0.001) but not at 3 months. The study also demonstrated a significant reduction in the response to the glucose tolerance test at both 2 months (p<0.001) and at 3 months (p<0.01). The Eugenia jambolana arm was compared with the Chlorpropamide arm at 1 month. The Chlorpropamide arm did not show a significant reduction in fasting blood sugar as did the Eugenia jambolana arm. Both the Chlorpropamide and the Eugenia jambolana arms showed a significant reduction in serum blood sugar 2 hours after the glucose tolerance test (p<0.05 and p<0.001, respectively). The study also revealed statistically significant reductions in all of the symptoms associated with diabetes (polyurea, polydipsia, polyphagia, weight loss, weakness, leg cramps, and joint pain) at 1 month, 2 months, and 3 months. The authors noted that of the original 30 patients enrolled in the study, only 9 were still in the study at 3 months. No adverse effects were reported from this trial.

Table 17. Study results for herb-treated arm, Kohli and Singh, 1993

| Pre-study | 1 month | 2 months | 3 months
Fasting blood sugar (mg/dl) | 163 | 129 (p<0.001) | 99.64 (p<0.001) | 130.1 (NS)
1-hour post-prandial blood sugar (mg/dl) | 279 | 222.68 (p<0.001) | 183.55 (p<0.001) | 220.33 (p<0.001)
2-hour post-prandial blood sugar (mg/dl) | 304.67 | 249.00 (p<0.001) | 192.62 (p<0.001) | 226.00 (p<0.001)

NS=nonsignificant

The researchers concluded that Eugenia jambolana produces symptomatic relief of diabetes and a simultaneous reduction in fasting glucose levels. Given the widespread availability, inexpensive price, and lack of side effects of this herb, the authors recommend making Eugenia jambolana part of the regimen of all NIDDM (type 2) patients. The study's significant design flaws make it difficult to draw the same conclusions.

Baskaran, Ahamath, Shanmugasundaram, et al. (1990) studied the effects of GS4, a specific isolate of Gymnema sylvestre, on the blood sugar and cholesterol levels of type 2 diabetic patients. Forty-seven patients (23 percent female, age 40–63) were recruited. The patients were classified into two arms. Arm I consisted of 22 diabetic patients on oral hypoglycemic therapy, which was continued during the trial, plus the herbal therapy with gymnema. The duration of diabetes in this arm varied from 1 to 12 years (mean = 4.6 years), and the blood glucose control was generally noted to be poor. Arm II consisted of 25 type 2 diabetic patients on conventional medications alone. The duration of diabetes in this arm ranged from 1–5 years (mean = 2.7 years). No socioeconomic characteristics were reported for the patients. Although the arms were reasonably matched for age and Broca index (percent of ideal body weight), they were not clinically equivalent at the start of the trial. Importantly, based on analysis of individual patient data in the study, the two arms were statistically different at baseline with respect to fasting blood sugar.

The intervention consisted of GS4, which is a water-soluble acidic fraction of an ethanol extract of the leaves of Gymnema sylvestre. The dose was 400 mg/day given to the patients in Arm I for a period of 18–20 months in addition to their conventional oral hypoglycemics. Patients in Arm II continued to take their conventional medicines only.

The study results were as follows. In Arm I after 12 months of followup, mean FBS improved from 174 mg/dl to 124 mg/dl (p<0.001); hemoglobin A_1c_ improved from 11.9 percent to 8.48 percent (p<0.001); cholesterol improved from 260 mg/dl to 231 mg/dl (p<0.001); and triglycerides improved from 170 mg/dl to 142 mg/dl (p<0.001). In the Arm II comparison group after 12 months of followup, mean FBS changed from 150 mg/dl to 157 mg/dl; mean hemoglobin A_1c_ went from 10.2 percent to 10.47 percent; mean cholesterol worsened from 252 mg/dl to 261 mg/dl (p<0.05); and mean triglycerides changed from 148 mg/dl to 164 mg/dl (p<0.001). Virtually all patients in Arm I developed hypoglycemic symptoms, and the dose of their normal oral hypoglycemic agent needed to be changed or stopped. Most of the patients in Arm I reported a sense of well being, less exhaustion, and less pain. Five of the 22 patients in Arm I were able to discontinue their oral hypoglycemic agent.

The authors concluded that GS4 supplementation in type 2 diabetic patients has an advantage over conventional therapy alone in reducing hyperglycemia and hyperlipidemia. The lack of a placebo comparison arm, lack of random allocation, the small number of patients, and baseline differences between arms are the drawbacks of this study. The Jadad score is 0.

Shanmugasundaram, Rajeswari, Baskaran, et al. (1990b) reported the effect of an herbal compound on blood glucose, insulin requirements, and cholesterol in type 1 and type 2 diabetic patients. The patients (n=64) were recruited from the outpatient departments of Ambedkar Institute for Diabetes in Madras, India. All the patients were free from diabetic complications. No socioeconomic characteristics were reported. The patients were studied in two arms. Arm I consisted of 37 type 1 diabetic patients (ages 8–30 years, percent female not reported) who were on insulin therapy and served as controls. Arm II consisted of 23 type 1 diabetic patients (ages 10–31 years, 39 percent female) and 4 type 2 diabetic patients (ages 44–50 years, 25 percent female) who continued their insulin in addition to taking the herbal intervention. The clinical equivalence of the two arms at baseline was not mentioned. The intervention drug was GS4, a re-crystallized precipitate of the alcoholic extract of the acidic fraction of Gymnema sylvestre; a dose of 400 mg/day was given to patients in Arm II alone. Patients in Arm I served as controls and continued to take their insulin. They were given the same care and education as Arm II patients.

Study results are summarized in Table 18. (Data are reported for the longest followup interval for all patients, 6–8 months.) Some patients continued in the trial for a total of 10–12 months.

Table 18. Study results for Shanmugasundaram, Rajeswari, Baskaran, et al., 1990b

| Insulin required (units/day) | Fasting glucose (mg/dl) | Hemo-globin A_1c_ (%) | Choles-terol (mg/dl) | Triglyce-rides (mg/dl) | Free fatty acid (mg/dl)
Arm I
Initial | 55 | 233 | 12.7 | 225 | 124 | 84
At 10–12 months | 55 | 224 | 11.8 | 209 | 112 | 80
Arm II | 60 | 232 | 12.8 | 206 | 134 | 84
Pre GS4
At 6–8 months | 45 | 177 | 9.5 (p<0.01) | 208 | 121 | 77

There were 11 dropouts (40 percent) in the treatment arm (5 left the city, 1 had frequent episodes of hypoglycemia, and 5 did not get continued support from their families). All patients in Arm II developed hypoglycemic episodes, and their insulin doses were reduced by 10 units at a time. Based on these results, the authors concluded that, compared to the insulin-only arm, those patients who received GS4 supplementation had a reduction in insulin requirement, improved blood glucose homeostasis, and better control of hyperlipidemia. The drawbacks of this study were the lack of a placebo comparison arm, lack of random allocation and blinding, as well as a high dropout rate. The Jadad score was 1.

#### Effect Size Analysis: Difference of Differences for RCTs and CCTs

As described in Chapter 2, the studies selected for inclusion in Evidence Table 1 were subjected to further analysis. For each of the three outcomes, a common effect size known as a “difference of differences” was estimated for each RCT or CCT that met the inclusion criteria and had data available for that outcome. This statistic is calculated in three steps:

- Step 1—Calculate the difference in the outcome associated with the intervention for the treatment arm (the post-intervention mean value minus the pre-intervention mean value).
- Step 2—Calculate the same difference for the nonherbal arm.
- Step 3—Subtract the results of Step 2 from those of Step 1.

We then constructed a confidence interval for this estimate as described in Appendix K. Given the marked heterogeneity of the studies selected, these effect sizes are only compared graphically across studies in Figure 1; they are not pooled together into an overall effect size.

To facilitate the comparison of these study outcomes, we constructed side-by-side forest plots for the three outcomes: fasting glucose (left), post-prandial glucose (center), and hemoglobin A_1c_ (right). Each effect size is plotted as a point with its 95-percent confidence interval shown as a horizontal line. Placing the plots side-by-side allows the reader to compare outcomes within a study (across the same horizontal line) and across studies (vertically). We added a vertical reference line at zero (no difference between pre-intervention and post-intervention mean values) for ease of reference. To further help the reader, we state “favors treatment” at the bottom of the forest plots to indicate values of the effect size that are associated with a beneficial effect of the intervention.

The two RCTs are presented first, in descending alphabetical order according to the herbal agent used. These are followed by the five CCTs. The herbal agents are designated by their common English name, if one exists, or by their botanical name. All the agents reported in Figure 1 were tested as single agents.

Figure 1 demonstrates the following results: five studies favor treatment to reduce fasting blood sugar; the remaining two studies, which tested Coccinia indica and Eugenia jambolana respectively, had statistically nonsignificant results. Only four of the seven studies measured post-prandial blood sugar. Of those four studies, only two favored treatment; two did not clearly support treatment. Two of the seven studies measured hemoglobin A_1c_, and both favored treatment.

The confidence intervals for some effect sizes are very narrow, which concerned us given the small sample sizes of the studies. We would not expect such precision based on these numbers of patients. We hypothesized that some studies that reported a statistic as the “standard deviation” meant the standard deviation of a mean (the standard error), not the standard deviation of the underlying population. If we mistakenly use a standard error in the calculations discussed in Appendix K, we would construct an overly narrow confidence interval. We attempted to check the accuracy of the data, for example, by inferring from a reported test statistic or p value what the standard error was; but we were unsuccessful at providing adequate evidence to make any changes to the data. We alert the reader to the fact that some of the confidence intervals seem unnaturally narrow. We note that Chandola, Tripathi, and Udupa (1980a), Baskaran, Ahamath, Shanmugasundaram, et al. (1990), and Shanmugasundaram, Rajeswari, Baskaran, et al. (1990b) all reported patient-level data from which we could calculate our results directly; therefore, the confidence intervals are realistic for the effect sizes of these studies.

## Pre/Post Comparison Studies

The 15 studies that met the inclusion criteria (see “Quality of the Evidence” section) for Evidence Table 2 had treatment arms that reported blood glucose and/or hemoglobin A_1C_ values before and after herbal interventions, i.e., that had pre/post data available. Herbs were tested both singly (seven studies), in combination (seven studies), or both singly and in combination (one study). These studies are summarized in Evidence Table 2, and the detailed descriptions of their results follow. All of these studies are limited by the lack of randomization. Many are also limited by small sample size and short study duration.

### Single Herbs

Chandola, Tripathi, and Udupa (1980a) performed a series of three studies with type 2 diabetic patients to study the hypoglycemic effects of Cinnamonum tamala. All three studies are discussed together in the synthesis of evidence under the heading “Controlled Clinical Trials” above. Only one of the studies was a CCT; the other two were case series of a single herb that had pre/post data available. Of these latter two studies, only the first had an adequate sample size to be included in Evidence Table 2 and the associated Figure 2.

Kamble, Kamlakar, Vaidya, et al. (1998) studied the effects of Coccinia indica on enzymes in the glycolytic and lipolytic pathway in diabetes.^8^ Thirty patients had documented NIDDM (type 2), of which 15 had mild diabetes (fasting blood glucose levels of 120 to 140 mg/dl) and 15 had severe diabetes (fasting blood glucose >200 mg/dl). There were 30 normal healthy controls. The age, gender, and other demographic and socioeconomic characteristics of the patients were not provided.

The large decrease in fasting blood glucose effect size excludes this study from Figure 2.

Patients with severe diabetes were given 50 mg/kg of body weight of a dried extract of Coccinia Indica, which was taken with water twice a day before meals. It was not noted whether these patients were taking any concurrent allopathic medications.

The researchers reported that the mean fasting blood sugar level of the severe diabetic patients treated with Coccinia decreased from 365 mg/dl to 112 mg/dl (p not reported). There were also statistically significant decreases reported in levels of glucose-6-phosphatase, lactate dehydrogenase, and lipoprotein lipase (p<0.001).

The short duration of the study and small number of patients are weaknesses of this study. Although these weaknesses limit the generalizability of the conclusions, the results support the argument for further research on Coccinia indica.

Kuppurajan, Seshadri, Revathi, et al. (1986), at the Central Council for Research in Ayurveda and Siddha, studied the hypoglycemic effect of Coccina indica. A series of patients with adult onset diabetes were recruited (source not described). Although gender was not described, the patients were between 30 and 60 years of age. Patients were included if they were recently diagnosed NIDDM (type 2) confirmed by GTT. Patients were excluded for conditions such as severe hypertension and tuberculosis. Patients were given Coccina indica in the form of a powder made from fresh stems of the plant, which had been pharmacognostically identified prior to being harvested. The powder was placed in capsules and administered to patients at doses of 3 g/day (for mild diabetes) and 4 g/day (for moderate diabetes), in divided doses for 30 days. Patients' urine was tested for sugar on day 11 and day 21. A glucose tolerance test was done on day 31. A total of 16 patients completed the study (10 with mild diabetes and 6 with moderate diabetes). Out of the 10 mild diabetic patients, 8 showed good response to treatment and 2 did not respond; out of the 6 moderate diabetic patients, 4 showed good response to treatment and 2 had no response. Patients who responded showed significant benefit from the treatment in their fasting and 2-hour post-prandial glucose values.

Data were presented separately for the responder and nonresponder arms (Tables 19-21). However, there was no description of differences between responders and nonresponders. Thus no data are available to select patients who would be most likely to respond to the treatment. The authors did demonstrate that some patients will respond favorably to the drug at the stated dosage levels. Lipids were not significantly affected in any patients. The short duration of followup is a significant weakness of this study.

Table 20. Effects on mean glucose tolerance test in responder cases (n=12), Kuppurajan, Seshadri, Revathi, et al., 1986

| Fasting | 30 min | 60 min | 90 min | 120 min
Mean difference ± SE | -31.6 ± 8.14 | 20.9 ± 11.9 | -58.28 ± 13.3 | -59.0 ± 19.4 | -74.3 ± 21.5
P value | <0.01 | NS | <0.01 | <0.02 | <0.01

SE=standard error; NS=nonsignificant; min=minute

Table 19. Blood glucose levels from Kuppurajan, Seshadri, Revathi, et al., 1986

| Fasting blood sugar (mg/dl) (SD) | | 2-hour post-prandial blood sugar (mg/dl) (SD)
| Initial | Final | Initial | Final
Responders (n=12) | 127.1 (11.2) | 95.5 (4.9) | 242.4 (32) | 168.4 (14.8)
Non-responders (n=4) | 123.0 (29.7) | 182.5 (80) | 205.0 (46.4) | 285.5 (80.2)

SD=standard deviation

Table 21. Effects on mean glucose tolerance test in nonresponder cases (n=4), Kuppurajan, Seshadri, Revathi, et al., 1986

| Fasting | 30 min | 60 min | 90 min | 120 min
Mean difference ± SE | 59.5 ± 50.9 | 44.0 ± 19.8 | -17.75 ± 25.1 | -40.5 ± 26.5 | -80.2 ± 46.1
P value | NS | Borderline | NS | NS | NS

SE=standard error; NS=nonsignificant; min=minute

Kuppu Rajan, Srivatsa, Krishnaswami, et al. (1998) conducted a case series study with type 2 diabetic patients using fenugreek (Trigonella foenum-graecum), also known as methica churna in Hindi.

Patients, referred from a Western mainstream practice, were studied in collaboration with a research unit in indigenous medicine. Fifteen patients (ages 30–60 years, 9 males, 6 females) with type 2 diabetes confirmed by GTT were enrolled. No inclusion/exclusion criteria were described. All patients were given encapsulated fenugreek powder; each capsule contained 0.5 g of the powder. The total dose was 9 g/day given in three divided doses for 3 months. At the end of 90 days, the glucose tolerance test and tests for blood urea nitrogen, serum creatinine, cholesterol, uric acid, and triglycerides were repeated. Statistically significant reductions between initial and final blood sugar values at 2 hours were observed. The most significant reductions between initial and final measures for the other values were seen in serum cholesterol (mean difference –17.40 ± 4.22, p<0.001) and in serum triglycerides (mean difference -13.25 ± 6.51, p<0.05). Study results are shown in Table 22.

Table 22. Study results of Kuppu Rajan, Srivatsa, Krishnaswami, et al., 1998

Parameter | Initial mean value (SD) | Final mean value (SD) | Level of significance
Fasting glucose (mg/dl) | 148.00 (64.4) | 128.27 (12.70) | NS
2-hour post-prandial blood sugar (mg/dl) | 314.27 (225.19) | 264.80 (21.31) | P< 0.02
Cholesterol (mg/dl) | 205.33 (9.58) | 187.93 (7.30) | P < 0.001
Triglycerides (mg/dl) | 142.07 (13.40) | 129.42 (8.98) | P < 0.05

SD=standard deviation; NS=nonsignificant; h=hour

The authors concluded from this study that the traditional use of methica churna (fenugreek) for diabetes is justified by the evidence at the dosage and duration used in this study. It is further noted that the effect on lipids is apparently greater than the effect on blood sugar.

Kumar, Kumar, and Sharma (1999), in a CCT, reported the effects of three different herbal preparations—two combinations and one single herb respectively—on three arms involving type 2 diabetic patients. A total of 111 patients (55 percent female) were recruited from the outpatient department of the Regional Research Center for Ayurveda, Jammu, India. The patients had a fasting blood sugar between 120 mg/dl and 300 mg/dl; had the disease for less than 10 years; and did not have any diabetic complications. Socioeconomic status was reported for class (high class, 30 percent; middle class, 49 percent; low class, 21 percent). The authors did not report if the arms were clinically equivalent prior to the trial.

Patients were classified into three arms. Arm I (n=30) received Ayush-82, a combination of seeds from Mangifera indica, Syzygium cuminii, and Momordica charantia as well as leaves of Gymnema sylvestre and the mineral preparation known as Shuddha Shilajit, which is black bitumen purified in Triphala water. (Triphala is a combination of Terminalia chebula, Terminalia bellerica, and Emblica officinalis.) One gram of Ayush-82 was given three times daily for 6 weeks. Arm II (n=30) received Chandraprabhavati, 1 g; Trivanga bhasma, a mineral preparation, 250 mg; and Vijayasara Kwatha (Pterocarpus marsupium), 25 ml. This treatment was taken daily for 6 weeks. Arm III (n=51) received 3 g of powdered Trigonella foenum graecum (fenugreek) seed taken three times daily for 6 weeks.

The study results were as follows. In Arm I patients, fasting blood sugar improved from 169.17 mg/dl to 120.9 mg/dl (p<0.001), and post-prandial blood sugar fell from 218.4 mg/dl to 172.9 mg/dl (p< 0.001) after treatment; cholesterol levels decreased from 251.6 to 225.33 (p< 0.001) after treatment. In Arm II patients, fasting blood sugar decreased from 168.37 mg/dl to 119.2 mg/dl (p<0.001), and post-prandial blood sugar fell from 234.07 to 181.83 mg/dl (p<0.001); cholesterol levels decreased from 239.1 to 223.63 after treatment (p<0.001). In Arm III patients, fasting blood sugar decreased from 174.63 to 121.06 mg/dl, and post-prandial blood sugar decreased from 236.53 to 183.83 mg/dl (p<0.001); cholesterol levels also decreased from 218.14 mg/dl to 198.29 (p<0.001) after treatment. In all three arms there was significant improvement in the symptoms of polyuria, polyphagia, polydipsia, tiredness, palpitations, anxiety, and pruritis.

The authors concluded that the preparations tested had a highly significant hypoglycemic effect and were effective in symptomatic relief as well. They noted that there were no hypoglycemic episodes despite the significant decrease in blood sugar. The Jadad score for this trial was 0.

Sharma, Sarkar, Hazra, et al. (1996a), in a CCT, studied the effects of fenugreek seeds in 60 NIDDM (type 2) patients (25 percent female, ages 30–70 years) at the S.N. Medical College in Agra, India. The patients were selected from the outpatient clinic, and all had uncontrolled blood sugar levels. Ten normal subjects were also studied; however the article did not report data sufficient for a statistical comparison of these two arms. Of the 60 diabetic patients, 22 had mild disease, 35 had moderate disease, and 7 had severe disease.^9^ Forty of the 60 patients were taking oral hypoglycemic agents, which were continued throughout the study. Patients were instructed to begin a 300 g carbohydrate diet and continue it for a 7-day control period after which a baseline glucose tolerance test was performed. The study also included 10 control patients (30 percent female, ages 30–70 years) chosen from healthy volunteers at the medical center. There was no blinding of either the patients or the researchers.

These are the numbers reported in the article, although they total to 64, not 60.

Patients were given powdered fenugreek seeds, 12.5 g twice a day, for 24 weeks in addition to their carbohydrate-restricted diet. Some patients complained of diarrhea and excess flatus, all of which resolved within 3 to 4 days. No other adverse effects from the fenugreek seeds were observed.

Diabetic symptoms, such as polyuria, polyphagia, and polydipsia, improved in a majority of patients. The quantitative results are reported in Table 23.

Table 23. Study results for diabetic arm of Sharma, Sarkar, Hazra, et al., 1996a

Time (hours) | Blood glucose (mg/dl) | | Serum insulin (mU/L)
| Initial | 24 weeks | Initial | 24 weeks
0 | 152.45 | 112.52 (p<0.001) | 16.2 | 17.3
2 | 259.53 | 172.41 (p<0.001) | 38.2 | 25.8 (p<0.05)

In addition, mean urinary glucose excretion was reduced by 13 percent (p<0.001), and there was a significant reduction in glycosylated hemoglobin of 1.2 percent (p<0.001).

The researchers concluded that the addition of 25 g of fenugreek seed to the daily diet of NIDDM (type 2) patients could be an effective supportive therapy in the prevention and management of long-term complications of diabetes. The results of this study are encouraging, and the use of fenugreek seed in the management of NIDDM (type 2) patients merits further investigation. The Jadad score for this trial was 0.

The Indian Council for Medical Research (1998) and its collaborating centers studied the effects of the bark of Pterocarpus marsupium on 223 mild type 2 diabetic patients. Only patients with newly diagnosed or untreated diabetes were admitted to the study. After 1 month of diet therapy, 124 of these patients had fasting blood glucose between 120 mg/dl and 180 mg/dl and post-prandial blood glucose levels from 180 to 250 mg/dl and were admitted to the herbal study. Of 223 patients enrolled in the diet phase of the study, 15 dropped out during diet therapy; 49 were controlled by diet alone; 35 had blood sugars too high after the diet phase to enroll in the herb study; and 24 dropped out after the herbal study began. In addition, one patient was excluded from the analysis and two withdrew from the study for consistently high blood sugars; this left 97 patients available for analysis. Patients who had any systemic diseases, body mass index < 19, or who were pregnant were excluded from entering the study. The ages of the patients ranged from 35 to 60 years; gender and socioeconomic status were not reported.

All patients were given an extract (aqueous decoction subsequently dried) of the bark of Pterocarpus marsupium. Initially, 1 g of drug was given twice a day. This was increased to 1.5 g twice a day and then to 2 g twice a day, as required to control blood sugar. All patients were also given a standard diet, and they were discouraged from taking drugs for any other ailment.

Results were reported as follows. Four of the 97 patients had to be withdrawn because of post-prandial blood sugar > 300 mg/dl on two occasions. Mean fasting blood sugar of the remaining patients fell from 151 mg/dl to 119 mg/dl (p< 0.001). Mean post-prandial blood sugar fell from 216 mg/dl to 171 mg/dl (p< 0.001), and mean hemoglobin A_1c_ (reported only for 67 patients) fell from 9.8 to 9.4 (p<0.001). Control of glucose was achieved in 67 of 93 patients, and no hypoglycemic episodes were noted. There was also a reduction in polyuria in all patients who had it, as well as a modest decrease in polyphagia and polydipsia. On a three-point quality of life scale (fatigue, sense of well being, and optimization of weight), there was mild improvement.

The authors concluded that Pterocarpus marsupium is useful in the treatment of newly diagnosed and untreated diabetic patients. The short duration of the study is a limitation. The variation in the dosage is not adequately controlled for, nor are the results reported in relation to the dosage required for control. This lack of detail is another weakness in the study.

Goyal and Tiwari (1999) reported the effects of Vinca rosea (now Catharanthus roseus) on blood sugar levels in a CCT consisting of 40 diabetic and 10 normal patients. The source, duration of disease, age, and sex of the patients were not mentioned. Socioeconomic status of patients, inclusion and exclusion criteria, and the presence of complications were not reported.

The trial drug was prepared using the leaves of Vinca rosea made into a paste. The patients were classified into four arms. Arm I (n=25) consisted of diabetic patients with fasting blood sugar ranging from 100 mg/dl to 200 mg/dl. They received 5 g of the trial drug twice a day for 30 days. Arm II (n=10) consisted of diabetic patients with fasting blood sugar levels <200 mg/dl. They were given 5 g of the trial drug twice a day along with the oral hypoglycemic agent glipizide given at 2.5 mg once a day for 20 days. Arm III (n=10) consisted of subjects who were of normal health and had normal fasting blood sugars. They were given 5 g of the trial drug twice a day for 10 days. Arm IV (n=5) consisted of diabetic patients who were given a single 10 g dose of the trial drug.

Results were as follows. In Arm I patients, the average fasting blood sugar decreased from 131.37 mg/dl to 98.98 mg/dl (p< 0.001) after 1 month of treatment. Post-prandial blood sugar fell from 224.90 mg/dl to 144.24 mg/dl after 30 days of treatment (p<0.001). In Arm II patients, the average fasting blood sugar fell from 217.45 mg/dl to 91.55 mg/dl (p<0.001) after 20 days of treatment. Post-prandial blood sugar fell from 314.50 mg/dl to 140 mg/dl (p<0.001). In Arm III and Arm IV there was no significant decrease in fasting or post-prandial blood sugars. Symptomatic improvement was assessed in Arm I and Arm II patients only. These patients showed statistically significant (p<0.001) improvement in polyuria, polydipsia, and weakness, while there was no significant improvement in polyphagia, cramps, libido, joint pain, and weight loss.

The authors concluded that treatment with the leaves of Vinca rosea caused a significant improvement in blood sugar levels of diabetic patients and also improved the symptoms of polyuria, polydipsia, and weakness. The authors did not describe how they assigned patients to the study arms. The Jadad score for this trial was 0.

### Combinations and Formulas

Chowdhary, Dua, Bharti, et al. (1998) studied the effect of Ayush-82, an Ayurvedic formula, on 100 non-insulin dependent diabetic patients. The patients (48 percent female) were randomly selected from both the inpatient and outpatient departments of the Central Research Institute of New Delhi to participate in the study. Patients were included if they were diabetic for less than 3 years and had no evidence of diabetic complications. In this study, 52 percent of the patients were between 40 and 55 years old, and 48 percent were between 55 and 70 years old. Socioeconomic status was reported for both education level and income (22 percent high income, 50 percent middle income, 28 percent low income; 30 percent no education, 41 percent school level, 28 percent college level).

The drug treatment, Ayush-82, contained four herbs: the seeds of Mangifera indica, Syzygium cuminii 10, and Momordica charantia, and the leaves of Gymnema sylvestre. Five grams of the powder was given three times per day for 6 weeks. This preparation was given in conjunction with ShuddhaShilajit, a mineral preparation of black bitumen purified in Triphalawater (Triphala is a combination of Terminalia chebula, Terminalia bellerica, and Emblica officinalis.). The SudhaSilajitu was given in a 500 mg dose twice a day for the 6-week period. All patients were advised to consume a 1,200-calorie diet daily. Patients who were taking oral hypoglycemic medication at the start of the study were withdrawn from their drugs after 2 weeks of treatment with the Ayurvedic formula. No comparison arm was included in this study.

Also known as Eugenia jambolana.

The results were as follows. Average blood sugar prior to treatment was 169.33 mg/dl, and after 6 weeks of treatment it was 144.20 mg/dl. The mean fall in fasting blood sugar was 25.21 mg/dl, and this was significant (p<0.001). Likewise, post-prandial blood sugar fell from an average of 249.6 mg/dl pre-treatment to 219.2 mg/dl post-treatment for an average fall of 30.43 mg/dl (p<0.001). Despite the significant decline in blood sugar, only 25 percent of patients were reported to have achieved good or complete control of their diabetes, 17 percent of patients were mildly controlled, and 47 percent did not have their diabetes controlled by the end of the study. During the treatment period, there was an improvement in the patient reporting rate of polyuria (40 percent to 22 percent), polydipsia (38 percent to 18 percent), polyphagia (24 percent to 16 percent), and weakness (47 percent to 23 percent).

The researchers concluded that Ayush-82 exerted a beneficial effect in NIDDM (type 2) patients, making it possible for them to reduce their use of pharmaceuticals and to improve their physical symptoms. The ambiguity of the process of withdrawal of oral medication is a design problem of this study. Further, the clinical response was not great since half the patients still remained uncontrolled.

Kumar, Kumar, and Sharma (1999) is described above under “Single Herbs.” It is listed in this section as well because combinations of herbs were used in two of the three study arms.

Pandey, Rajagopalan, and Chowdhary (1995) studied the effects of Ayush-82, an Ayurvedic herbal formulation, on diabetic patients. A total of 350 type 2 diabetic patients attending the outpatient department of the Central Research Institute of Ayurveda in New Delhi were screened. Out of these, 80 patients who were older than 40 years and who had the disease less than 3 years, with no neuropathy, nephropathy, retinopathy, or current infections and who were compliant with medications were selected. Of these 80 patients, 30 (46 percent female) were between 40 and 49 years old; 38 patients (55 percent female) were between 50 and 59 years old; and 12 patients (25 percent female) were more than 60 years old. Among the patients, 8.7 percent belonged to low-income groups, 76 percent belonged to middle-income groups, and 15 percent belonged to high-income groups.

The intervention consisted of the herbal formula Ayush-82. This contains four herbs: the seeds of Mangifera indica, Syzygium cuminii, and Mormodica charantia and the leaves of Gymnema sylvestre. These herbs were powdered together, and 5 g of the powder was taken three times a day for 24 weeks. This preparation was given in conjunction with Shuddha Shilajit, a mineral preparation of black bitumen purified in Triphala water. A 500 mg dose of this formulation was given twice a day for the 24-week duration. All patients were advised to consume a 1,200-calorie diet. Additionally, patients who were taking an oral hypoglycemic agent were withdrawn from this drug over a 15-day period prior to commencement of the study.

Additionally, the researchers reported that on a physician rating scale, 61 percent of the patients had a good response to therapy, 12.9 percent had a fair response, and 25.9 percent had a poor response.

Study results are shown in Table 24. The authors concluded that the Ayurvedic formulation Ayush-82 lowers both fasting and post-prandial blood sugar levels in both sexes. The lack of a control arm and the ambiguity of the process of withdrawal of oral hypoglycemic agent are weaknesses of this study.

Table 24. Study results for Pandey, Rajagopalan, and Chowdhary, 1995

Values | Blood sugar before treatment (mg/dl) | Blood sugar after treatment—24 weeks (mg/dl)
Fasting (males, n=42) | 195 ± 48 | 131 ± 64 (p<0.001)
Fasting (females, n=38) | 191 ± 48 | 141 ± 64 (p<0.001)
Post-prandial (males, n=42) | 288 ± 74 | 204 ± 89 (p<0.001)
Post-prandial (females, n=38) | 279 ± 105 | 201 ± 83 (p<0.001)

Note: The results were not reported for males and females as a whole group.

Shankar and Singhal (1995) studied the effects of Abraga Chendooram, an Ayurvedic formulation, on 130 patients with NIDDM (type 2). Patients were selected from the ambulatory clinic at Safdarjang Hospital in New Delhi. All patients (n=130, 43 percent female, ages 20–70 years) chosen for this study were given a glucose tolerance test and failed dietary control of their blood sugar for 15 days. The socioeconomic characteristics of the patients were not mentioned.

Patients were given a formula called Abraga Chendooram, which consists of Abragam (purified black mica, 80 g); Vengaram (dehydrated borax, 0.5 g); Saranaiver charu (juice of the root of Trianthema decandra Linn.); Adathodaielai charu (juice from the leaves of Adhatoda zeylanica Linn.); and Alam vizhuthu kudineer (root of Ficus benghalensis Linn.). Patients were given 200 mg of the drug (in gelatin capsules) twice daily for 45 days. During this period, caloric intake was restricted to 25 calories per kg of ideal body weight. No mention was made of whether or not any patients were taking any concurrent allopathic medications for diabetes.

The study showed a statistically significant reduction in mean FBS from 172.3 mg/dl to 110 mg/dl, which was a difference of 62.30 mg (p<0.005), and a reduction in the PPBS from 267.7 mg/dl to 183.0 mg/dl, a difference of 84.70 mg/dl (p<0.005). The authors created a secondary classification system consisting of “good response” (FBS and PPBS at or below normal levels with disappearance of all symptoms); “moderate response” (FBS 120–140 mg/dl and PPBS 180–200 mg/dl with disappearance of major symptoms); and “no response” (no change in blood sugar level or symptoms). The study showed that 57.69 percent of all patients had a good response, 26.93 percent showed a moderate response, and 15.38 percent showed no response. No adverse effects were reported from this study.

The researchers concluded that Abraga Chendooram reduces the blood sugar level in patients with mild to moderate NIDDM (type 2) when combined with dietary control; in 58 percent of cases, it brings blood sugar levels into the normal range. The short duration of followup is a design flaw of this study.

Maji and Singh (1995) reported the effects of an herbo-mineral preparation, D-400, on the blood sugar and cholesterol levels of diabetic patients. The patients (n=38, ages 35–76 years, percent female not reported) were classified into three arms. Arm I (n=19), consisted of patients who had failed therapy with oral hypoglycemic agents; Arm II (n=8) consisted of newly diagnosed diabetic patients who failed diet and exercise therapy; and Arm III (n=6) consisted of patients who were dependent on insulin therapy. The socioeconomic status of the patients and the clinical equivalence of the three arms were not reported.

The intervention consisted of an herbo-mineral compound, D-400, consisting of: Eugenia jambolana,^11^ Pterocarpus marsupium, Ficus glomerulata, Gymnema sylvestre, Momordica charantia, Ocimumsanctum, and Shilajit. The concentrations of each of these ingredients and the method of preparation were not mentioned. All three arms of patients received two tablets of the drug three times a day for 6 months. All the patients were given a standard diet with the number of calories determined by the patient's body mass index.

Also known as Syzygium cuminii.

Study results are provided in Table 25. The authors concluded that D-400 was effective in lowering blood sugar as well as cholesterol in patients who had failed oral hypoglycemic therapy and in newly diagnosed diabetic patients. It was less effective in patients who were already on insulin.

Table 25. Study results for Maji and Singh, 1995

| Arm I | Arm II | Arm III
Pre-treatment FBS (mg/dl) | 208.47 | 219.88 | 267.33
Post-treatment FBS (mg/dl) | 113.05 (p<0.01) | 109.00 (p<0.01) | 215.00
Pre-treatment PPBS (mg/dl) | 262.00 | 284.13 | 311.17
Post-treatment PPBS (mg/dl) | 141.16 (p<0.01) | 131.00 | 302.17
Pre-treatment cholesterol (mg/dl) | 194.82 | 182.57 | 182.83
Post-treatment cholesterol (mg/dl) | 172.00 (p<0.01) | 162.29 (p<0.01) | 166.50 (p<0.01)
Pre-treatment HDL (mg/dl) | 71.15 | 54.00 | 51.60
Post-treatment HDL (mg/dl) | 80.85 (p<0.05) | | 54.60
Pre-treatment LDL (mg/dl) | 170.73 | 118.25 | 168.40
Post-treatment LDL (mg/dl) | 149.64 (p<0.01) | 101.75 | 154.20

FBS=fasting blood sugar; PPBS=post-prandial blood sugar; HDL=high-density lipoprotein; LDL=low-density lipoprotein

Sircar, Ahuja, Natu, et al. (1996) reported the effects of the Ayurvedic formulation MA-471 on blood sugar levels, on hemoglobin A_1c_, and on cholesterol in 69 type 2 diabetic patients. Patients were recruited from the diabetic clinics of Gandhi Memorial Hospital and associated hospitals in Lucknow, India. Patients who were obese and had diabetic complications were excluded. No mention is made of the age and gender or the socioeconomic characteristics of these patients. Of the 69 patients, 9 were excluded (6 due to noncompliance and 3 due to other illnesses), leaving 60 patients completing the study.

The patients were classified into three arms. Arm I (n=15) consisted of patients who had never been on an anti-diabetic agent and were uncontrolled despite diet and exercise. Arm II (n=30) consisted of patients who were well controlled on an oral hypoglycemic agent. Arm III (n=15) consisted of patients who were not controlled despite maximum dose of oral hypoglycemic agents.

The Ayurvedic formulation MA-471 contained the herbs Enicostema littorale, Phyllanthus niruri, Eugenia jambolana, Melia azadirachta,^12^ Terminalia arjuna, and Aegle marmelos as well as a mineral preparation of black bitumen called Shilajit. The herbs were processed in an aqueous extract made from the leaves of the Aegle marmelos and from the fruits of the Momordica charantia. All patients received MA-471, two 500 mg tablets twice a day for an average of 9 months. Arm I patients received only MA-471; Arm II patients had their oral hypoglycemic agent withdrawn in addition to receiving MA-471; and Arm III patients continued to take both the oral hypoglycemic agent and MA-471. All patients were prescribed a standard diet.

Also known as Azadirachta indica.

In addition to the results shown in Table 26, significant improvement was also noted in the symptoms of polyuria, fatigue, and constipation; moderate improvement was noted in weakness, polydipsia, giddiness, muscle pain, palpitations, and anorexia.

Table 26. Study results for Sircar, Ahuja, Natu, et al., 1996

Values | Pre/post treatment | Arm I | Arm II | Arm III
Fasting blood sugar (mg/dl) | pre | 168.72 | 116.91 | 151.64
| post | 124 (p<0.001) | 103.64 (NS) | 102.90 (p<0.001)
Post-prandial blood sugar (mg/dl) | pre | 292.73 | 173.64 | 249.64
| post | 221.09 (p<0.001) | 171.82 (NS) | 171.27 (p<0.001)
Hb A_1c_ (%) | pre | 10.3 | 7.0 | 10.1
| post | 7.3 (p<0.05) | 7.6 (NS) | 6.4 (p<0.05)
Cholesterol (mg/dl) | pre | 236.4 | 242.3 | 227.6
| post | 182.3 (p< 0.01) | 171.5 (p<0.001) | 170.4 (p<0.01)
Triglycerides (mg/dl) | pre | 200.3 | 180.3 | 210.6
| post | 149.3 (p<0.05) | 148.7 (p< 0.01) | 159.2 (p<0.05)
HDL (mg/dl) | pre | 33.8 | 34.8 | 31.6
| post | 37.5 ( NS) | 39.8 (NS) | 35.8 (NS)

Hb=hemoglobin; HDL=high-density lipoprotein; NS=nonsignificant

The authors concluded that MA-471 has significant hypoglycemic properties as well as hypolipidemic properties. Additionally, they noted that there was great improvement in symptoms, which translated into better quality of life.

Shankar and Singhal (1994) reported the effects of a Siddha herbal preparation, Sandana Podi-a, on the blood sugar and symptoms of an arm of type 2 diabetic patients. The patients (n=20, 40 percent female, ages 20–70 years) were recruited from the diabetic clinic of Safdarjang Hospital, New Delhi, India. They had mild to moderately severe disease based on their blood sugar levels. Patients with diabetic complications were excluded from the study. No data about the socioeconomic status of the patients were reported.

The intervention consisted of Sandana Podi-a, an herbo-mineral preparation containing: 1 part Santalum album (sandalwood) saw dust; 1 part Andropogon citratus (lemongrass) root; 1 part Vetiveria zizanioides (vetiver) root; 1 part Syzygium aromaticum (clove) flower bud; 1 part Anacyclus pyrethrum (pyrethrum) root; 1 part of purified Shilajit, and 6 parts of Tinospora cordifolia sugar. This sugar was prepared by using whole chopped and crushed plant, which sat in water overnight. Then the water was decanted and placed in the sun, and the dried material was then re-suspended in water overnight. This process was repeated three times. Finally, the starch from this water was collected and dried. All ingredients for the preparation were ground into a fine powder, which was placed into capsules. All patients were given 300 mg of powdered drug twice a day for 45 days.

The results were reported as follows. The mean fasting blood sugar before treatment was 164.5 mg/dl, which decreased to 114.7 mg/dl after treatment. Mean post-prandial blood sugar before treatment was 281.7 mg/dl, and this decreased to 171.25 mg/dl after treatment. Both differences were statistically significant at p<0.01. Similarly, there was improvement in all symptoms, such as polyuria, excessive appetite, weight, giddiness, polydipsia, indigestion, vomiting, and abdominal pain.

The authors concluded that Sandana Podi-a reduces blood sugar and improves symptoms in mild-to-moderate type 2 diabetic patients. The short duration of the study is a major drawback.

Sivaprakasam, Rao, Yasodha, et al. (1984) studied the effects of two Siddha herbal preparations (Kadal Azhinjil choornam and Triphala tablets) on the blood sugar and symptoms of 25 type 2 diabetic patients. These patients were between the ages of 30 and 65 years (24 percent female) and were recruited from the outpatient department of the Central Research Institute for Siddha, Madras, India. The diagnosis of diabetes was made using Siddha as well as modern clinical and biochemical methods. There was no mention of the socioeconomic status or demographics of the patients.

All patients were asked to stop taking any medications that they had been on previously. The patients were then given two preparations. The first was Kadal Azhinjil choornam, botanically identified as Salacia chinensis. The roots and bark of this plant were used in a dose of 500 mg taken twice a day with water. The Triphala tablets contained three components: Terminalia chebula, Terminalia bellerica, and Phyllanthus emblica (also Emblica officinalis) in equal proportions. The 2.5 g Triphala tablets were taken three times a day with water. The total duration of the study was 120 days.

Results are shown in Table 27. No statistical tests of significance were reported for any of these percentages. Improvements in FBS values were reported before and after treatment. The mean blood sugar for the arm improved from 303.88 mg/dl to 184.68 mg/dl. Additionally, the authors reported that 4 patients showed a reduction in blood sugar of more than 50 percent; 11 showed a reduction of 40–50 percent; 6 showed less than a 40-percent reduction; and 4 showed no significant reduction.

Table 27. Study results for Sivaprakasam, Rao, Yasodha, et al., 1984

Clinical symptoms | Patients with symptom before treatment (%) | Patients with symptom after treatment (%)
Polyuria | 24 | 20
Polyphagia | 44 | 36
Polydipsia | 52 | 44
Nocturia | 52 | 40
Tiredness and general weakness | 48 | 40
Giddiness | 44 | 32
Pruritis | 32 | 24
Pruritis vulva | 12 | 8
Peripheral neuritis | 24 | 16
Blurring of vision | 48 | 16
Constipation | 52 | 40

The authors concluded that that the preparations have a definite effect on the blood sugar level. The ambiguity of reporting the results is a limitation of this study.

### Effect Size Analysis: Difference in Mean Values for Pre/Post Comparison Studies

As described in Chapter 2, the studies selected for inclusion in Evidence Table 2 were subjected to further analysis. All studies included had treatment arms with measurements of blood glucose, hemoglobin A_1c_, or post-prandial blood sugar before and after an intervention of either single herbs or groups of herbs. This subgroup of studies included CCTs, cohorts, and case series. For each of the three outcomes, a common effect size (a difference of means) was estimated for each arm of each study that met the inclusion criteria and had data available for that outcome. For a particular arm in a study, this statistic is the difference in the outcome associated with the intervention; i.e., the post-intervention mean value minus the pre-intervention mean value. We then constructed a confidence interval for this estimate as described in Appendix K. Given the marked heterogeneity of the studies selected, these effect sizes are only compared graphically across studies in Figure 2; they are not pooled together into an overall effect size. (Figure 2 is constructed similarly to Figure 1.)^13^

The study by Kamble, Kamlakar, Vaidya, et al. (1998) is excluded from Figure 2 because its effect size (post-mean/pre-mean fasting blood glucose = -235 mg/dl) was very extreme compared to the other studies on the graph. Fasting blood glucose is the only outcome of interest this study measured.

The studies in Figure 2 are in the following order: Studies or arms of studies using a single herbal preparation are listed first. Within that group, the studies are sorted alphabetically by the name of the herbal preparation used. Next, the group of studies that use a formula or a group of herbs and minerals is displayed. This group is sorted alphabetically in descending order by the name of the formula. Note that some studies with multiple arms will have listings in more than one place on the graph. Otherwise, the construction of Figure 2 is the same as for Figure 1.

As Figure 2 demonstrates, the majority of pre/post comparison studies using single herbs and formulas favor treatment. Hemoglobin A_1c_ is measured in only five of the studies. Two of those studies seem to strongly favor treatment; two are almost equivocal; and one does not favor treatment. As with Figure 1, we remind the reader that we relied on the data as reported in the individual studies, even though some of the resulting confidence intervals seem unnaturally narrow. We also note the Chandola, Tripathi, and Udupa (1980a) and Sivaprakasam, Rao, Yasodha, et al. (1984) reported patient-level data from which we could calculate our results directly; therefore, the confidence intervals are realistic for the effect sizes of these studies.

## Studies Not Included in Further Analysis

Forty studies did not qualify for inclusion in either Evidence Table 1 or Evidence Table 2. Thirty-one of these studies examine the effects of herbs used as single agents; five test herbal formulas only; three examine the effects of both single herbs and formulas; and one is primarily a diet study. Detailed descriptions of these studies^14^ are presented in Appendix L. Few conclusions can be drawn from this group of studies because of their basic design limitations including lack of randomization, lack of concurrent controls, lack of blinding, and small sample sizes.

See the bibliography to this report for reference citations for these studies, which are summarized in “Characteristics of Studies Not Included in Further Analysis” in Appendix L.