# Appendix H. List of Documents Received From India

1. Twenty-eight issues of the Journal of Research in Ayurveda and Siddha. These contain clinical articles on diabetes and cholesterol.
2. Cumulative Index (1980–1999) of the Journal of Research in Ayurveda and Siddha.
3. Central Council for Research in Ayurveda and Siddha Documentation Bulletin: Ayurveda and Siddha Research Abstracts, Vol. 20, No. 1.
4. Studies on Guggulu: Clinical and Experimental Trial of Guggulu in Lipid Disorders. Publication of the Central Council for Research in Ayurveda and Siddha.
5. Sample of Ph.D. thesis work of Dr. Adarsh Kumar. This is a compilation of all clinical research theses published in all Ayurvedic universities of India.
6. Seminar on Research Achievements of Ayurveda and Siddha, Research Papers. Publication of the Central Council for Research in Ayurveda and Siddha.
7. Clinical studies on kamala (jaundice) and liver disorders with Ayurvedic drugs.
8. Researches in Ayurveda: A Classified Directory of All India P. G. and Ph.D. Theses of Ayurveda by Dr. M. S. Baghel (1997).
9. Two sample issues of Ayu, the journal of the Institute of Post Graduate Teaching and Research in Ayurveda, Gujarat Ayurvedic University, Jamnagar, Gujarat, India.
10. List of journals available at the Central Council for Research in Ayurveda and Siddha library, New Delhi.