# Appendix G. Core Journals at the Central Council for Research in Ayurveda and Siddha Library

Ancient Science of Life

Journal of International Institute of Aur Ayurveda,

595, Trichy Road

Coimbatore - 647018 (T.N.)

Allied Ayurvedic Medical Research Abstracts

Sri Venkatarama Publications,

PO Box 8

Tirupathi - 517 507 (A.P)

Annals of Bhandarkar Oriental Research Institute

Bhandarkar Oriental Research Institute

Poona - 411004

The Antiseptic

Professional Publications (P) Ltd.

Satyasai Nagar

PO Box No. 2,

Madurai - 625 003 (T.N.)

Applied Botany Abstracts

National Botanical Research Institute

2, Rana Pratap Marg

Lucknow - 226 001

Arogya Sandesh

The Central Health Education Bureau

Kotla Road, Temple Lane

New Dehli - 11 00 02

Aryavaidyan

Arya Vaidya Sala,

KOTTAKKAL - 676 503

Malappuram District

Kerala Satate, India

A.U.S.H.D.I.

Anant Sundram Prakashan

[underlined: *] - B, Jayshree Apartment

Navyug Nagar, Vasai Road (W),

Mumbai - 401 202

AYU

Gujarat Ayurveda University

Dhanwantri Mandir

AJAMNAGAR - 361 008 Gurata Gujarat

AMRA

Journal of Research and Education in Indian Medicine

Ayurveda Chatna

Sobhag Club, Civil Line

Ajmar - 305 001

Ayurveda Varadni

Vardhi Ayurveda Sansathan

F - 1, Gali No. 16, Sad Nagar

Palam Colony

New Delhi - 110 015

Ayurveda Vikas

Dabur India Ltd.

3, Factory road, Ring Road

Near Safdarjung Hospital

New Delhi - 11 00 29

Ayurveda Visheshajna

320, Narala

Delhi - 110 040

British Medical Journal

(overseas edition)

U.K.

Bulletin of Botanical Survey of India

P - 8, Bargabourne Road

Calcutta

Deerghaya International

Ayurveda Academy, Opp. Mahatoba Temple

36, Kothrud

Pune - 411 029

Dhanwantri

Harish Pharma, Vijay Garh

Algarh - 202 001

Ethnobotany

Deep Publications,

A - 3/27A, DDA Flats

Paschim Vhar

New Delhi - 110 016

Indian Drugs

Indian Drugs Manufactures Associations

102 - B, Poonam Chember

Dr. A.B. Road, Worli

Mumbai - 400 018

Indian Forester

P.O. New Forest

Dehradun - 248 006 (U.P.)

Indian Journal of Botany

6-1-127/2, Khairatabad

Hyderabad

Indian Journal of Experimental Biology

National Institute of Science Communication (CSIR)

Dr. K.S. Krishnan Marg

New Delhi - 110 012

Indian Journal of Natural Products

Department of Pharmaceutical Sciences,

(formerly University of Sagar)

Sagar - 470 003 (M.P.)

Indian Journal of Pharmaceutical Sciences

Kalina, Santacruz East

Mumbai - 400 098

Indian Journal of Physiology and Pharmacology

Department of Physiology

All India Institute of Medical Sciences

Ansari Nagar, New Delhi - 110 029

Indian Journal of Plant Sciences

30, Baba, Bazar

Sagar - 470 002 (M.P.)

Indian Journal of Information Sciences

INSDOC (CSIR)

14, Satsang Vihar Marg

Opp. Sansanwal Marg

Special Institution Area

New Delhi - 110 067

Jeevaniya (Hindi & Eng.)

E -III/249, Sector - H

Aliganj

Lucknow - 226 020

Journal of Association of Physicians of India

Laud Mansion, 3^rd^ Floor

21, Maharashi Karve Road

Mumbai - 400 004

Journal of Bio-Sciences

Indian Academy of Sciences

C.V. Raman Avenue, P.B. No. 8005

Bangalore - 568 080

Journal of Diabetic Association of India

All India Institute of Diabetes

Rahaja Hospital Road

Mahim

Mumbai - 400 016

Journal of Library & Information Science

M/s Central News Agency

23/90, Connaught Circus

P.B. No. 374, New Delhi - 110 001

Journal of Medicinal and Aromatic Plant Sciences (Cromap)

Central Institute of Medicinal and Aromatic Plants (CIMAP)

P.O. CIMAP

Lucknow - 226 015

Journal of Natural Products

(Overseas Ed.)

Journal of National Integrated Medicinal Association of India

(NIMA)

G/2, Mohan Gunj, M.J. Phule Kunj

Mumbai - 400 014

Journal of Research & Education in Indian Medicine

B - 29/19, Lanka, Sanket Mochan Road

Varanasi - 221 005

Kaivalaya Hindi Masik

Prakash Mission, Tapovan - 249 192

Rishi Kesh, Tehri Garwal (U.P.)

Medicinal & Aromatic Plants Abstracts

National Institute of Science Communication

Dr. K.S. Krishnan Marg

New Delhi - 110 012

Mystic India

4, Synagogue Street (2^nd^ Floor)

(Facing Brabourne Road)

Calcutta - 700 001

Nirogdham

Nisorgopchar Varta

Bapu Bhawan

6, Ramabai Ambedkar Road

Old Tadiwala Road

Pune - 411 0011

Health Update

Society for Health Education and Learning Packages (HELP)

D-31, Defence Colony

New Delhi - 110 012

Planta Medica

Sachitra Ayurveda

Shree Baidyanath Ayurvd Bhawan Ltd.

Baidyanath Bhawan Road

Patna - 800 001

Science Today

7, Bahadur Shah Zafer Marg

New Delhi - 110 002

Social Welfare

B - 12, Institutional Area

South of I.I.T.

New Delhi - 110 016

Sudhanidhi

Dhanwantri Karyalaya

Vijay Garh

Ali Garh - 202 001

Yojana

Publication Division

Ministry of Information & Broadcasting (Govt. of India)

Old Secretariat

Delhi - 110 054

Yoga and Total Health

The Yoga Institute

Santa Cruz East

Mumbai - 440 055