# Appendix F. Questions for the Structured Interview

1. Do you know of any quality clinical trials being conducted in India to study Ayurvedic therapies?
2. Do you know of and have access to MEDLINE^®^ and other electronic databases?
3. If yes, do you know if the clinical trials that you know of would be available on MEDLINE^®^?
4. What are the important journals publishing Ayurvedic articles in India?
5. What are the major institutions conducting research in Ayurveda?
6. What languages are the clinical trials published in?
7. Which libraries are likely to keep copies of these publications?
8. Are there any databases, electronic or printed, that may have these publications?
9. Do you personally have access to journals with clinical trials?
10. If yes, what is the best way to search them for relevant articles?
11. Do you know if any particular Ayurvedic therapy for diabetes has clinical evidence pointing to it or against it?
12. If yes, could you specify the particular therapies?
13. Could you name the source of your information?
14. In your opinion, what is the quality of the evidence? (specify quality)