# Appendix E. List of Interviewees

Dr. Bibhas Ray, M.S., Ph.D.

Consultant—Coordination and Liaison for Drug Development

Dr. Reddy's Research Foundation

A-4/220, Kalkaji Extension

New Delhi, 110019

A. Venkateshwarulu, Ph.D.

President, Dr. Reddy's Laboratories,

Hyderabad, India.

Librarian

Topiwala National Medical College

Dr. A.L. Nair Rd.

Mumbai. 400008. India.

Dr. Dharmadhikari,

Dean

Podar Ayurvedic Medical College

Mumbai, India.

Dr. Kohli

Dept. of Kaya-Chikitsa

Podar Ayurvedic Medical College

Mumbai, India.

Dr. D. K. Mishra

Assistant Director (Ay)

GAMS, D.Ay.M

Central Council for Research in Ayurveda and Siddha

61–65 Institutional Area Opp. D Block

Janak Puri, New Delhi. 58

Dr. V. Ravi Shankar

Assistant Director (Siddha)

Central Council for Research in Ayurveda and Siddha

Ayush Bhawan, 61–65 Institutional Area, Opp. D Block, Janak Puri, New Delhi. 58

Dr. Adarsh Kumar

Assistant Research Officer

Central Council for Research in Ayurveda and Siddha

Ayush Bhawan, 61–65 Institutional Area, Opp. D Block, Janak Puri, New Delhi. 58

Mr. R. S. Yadava

Assistant Director (Library)

Central Council for Research in Ayurveda and Siddha

Ayush Bhawan, 61–65 Institutional Area, Opp. D Block, Janak Puri, New Delhi. 58

Dr. B. N. Sharma

Director

Central Research Institute of Ayurveda

Punjabi Bagh, New Delhi. 110063.

Dr. D. P. Chowdhury

Research Officer

Central Research Institute of Ayurveda

Punjabi Bagh, New Delhi. 110063.

Dr. Gurudeep Singh

Dean, Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India. 361008.

Dr. M. S. Baghel

M.D. (Ay) Ph.D., WHO Fellow

I/C Reader- Kayachikitsa

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University Jamnagar, Gujarat, India. 361008

Dr. Kulwant Singh

Department of Surgery

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University Jamnagar, Gujarat, India. 361008

Dr. H.N. Chandola

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University Jamnagar, Gujarat, India. 361008

Naim Asghar Bakari

Librarian, Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India. 361008

Dr. K. Raghunathan

Visiting Professor of Ayurveda

Ex Director, Central Council for Research in Ayurveda and Siddha

664/Sector28 Faridabad, Haryana. 121002