# Appendix C. Search Methodology for Ayurveda

## Initial Searches

### Search #1 (Dated 11/23/99)

Databases Searched and Years of Coverage

MEDLINE® | 1966-DEC 1999
HealthSTAR | 1975-DEC 1999
Allied and Complementary Medicine™^3^ | 1984-JAN 1999
MANTIS™ | 1880-NOV 1999
CAB HEALTH | 1983-OCT 1999
BIOSIS Previews® | 1993-SEP 1999
EMBASE® | 1974-NOV 1999

3 NOTE: Allied and Complementary Medicine™ was formerly called Allied and Alternative Medicine (AMED).

#### Search Strategy

AYURVEDA OR AYURVEDIC OR ADHATODA VASICA OR ALBIZZIA LEBBECK OR ANDROGRAPHIS PANICULATA OR BACOPA MONNIERA OR COLEUS FORSKOHLII OR COMMIPHORA MUKUL OR CRATAEVA NURVALA OR GYMNEMA SYLVESTRE OR HEMIDESMUS INDICUS OR INULA RACEMOSA OR PHYLLANTHUS AMARUS OR PICRORRHIZA KURROA OR TERMINALIA ARJUNA OR TYLOPHORA INDICA OR WITHANIA SOMNIFERA

Total number of records retrieved (including duplicates): 3,895

Total number of records retrieved (excluding duplicates): 2,565

### Search #2 (Dated 8/23/2000)

Databases Searched and Years of Coverage

CINAHL® | 1982-2000

#### Search Strategy

AYURVEDA OR AYURVEDIC OR ADHATODA VASICA OR ALBIZZIA LEBBECK OR ANDROGRAPHIS PANICULATA OR BACOPA MONNIERA OR COLEUS FORSKOHLII OR COMMIPHORA MUKUL OR CRATAEVA NURVALA OR GYMNEMA SYLVESTRE OR HEMIDESMUS INDICUS OR INULA RACEMOSA OR PHYLLANTHUS AMARUS OR PICRORRHIZA KURROA OR TERMINALIA ARJUNA OR TYLOPHORA INDICA OR WITHANIA SOMNIFERA

Total number of records retrieved: 70

## Final Search

### Search #3 (Dated 9/7/00)

Databases Searched and Years of Coverage

MEDLINE® | 1966-2000
HealthSTAR | 1975-2000
Allied and Complementary Medicine™^4*^ | 1984-2000
MANTIS™ | 1880-2000
CAB HEALTH | 1983-2000
BIOSIS Previews® | 1969-2000
EMBASE® | 1974-2000

4 See footnote 3.

#### Search Strategy

FENUGREEK OR TRIGONELLA WITHIN ONE WORD OF (FOENUMGRAECUM OR FOENUM (2W) GRAECUM OR FOENUMGRECUM OR FOENUM(2W)GRECUM) OR MOMORDICA CHARANTIA OR COCCINIA(W)INDICA OR CINNAMOMUM TAMALA OR PTEROCARPUS MARSUPIUM OR EUGENIA JAMBOLINA

AND

HUMAN (FOR ALL SEARCHES ON BIOSIS - BECAUSE OF THE LARGE NUMBER OF REFERENCES TO ARTICLES NOT RELATING TO HUMANS IN THIS DATABASE)

Total number of records retrieved: 773