# Appendix B. Acknowledgments

## Reviewers

We gratefully acknowledge the following individuals^2^ who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Individuals noted with an asterisk (*) were also members of the technical expert panel.

Mayer B. Davidson, M.D.

Director, Clinical Trials Unit

Professor of Medicine

UCLA School of Medicine

Charles R. Drew University of Medicine & Science

Los Angeles, CA

Michael S. Dick, MA

The Ayurvedic Institute

Albuquerque, NM

Dr. James Duke

Herbal Vineyard

Fulton, MD

David Frawley, OMD

Director

American Institute of Vedic Studies

Santa Fe, NM

Scott Gerson, M.D.

Ayurvedic Medicine of New York

New York, NY

David Heber, M.D., Ph.D.

Professor of Medicine

Director, UCLA Center for Human Nutrition

Los Angeles, CA

Simon Mills,* MA, MCPP, FNIMH

Director for the Center of Complementary Medicine

University of Exeter

Exeter, England

Lakshmi C. Mishra,* BIMS, M Pharm, Ph.D.

Professor of Research

Southern California University of Health Science

Whittier, CA

Shri K. Mishra,* M.D., MS, Doctor of Ayurveda

Professor of Neurology and Coordinator

Integrative Medicine

USC School of Medicine

USC Keck School of Medicine

Los Angeles, CA

Robert Schneider, M.D.

Director

Center for Natural Medicine & Prevention

Dean, College of Maharishi Vedic Medicine

Maharishi University of Management

Fairfield, IA

Betsy B. Singh,* PhD

Dean of Research

Southern California University of Health Sciences

Whittier, CA

Robert Svoboda, BS, BAMS, Ayurvedacharya

The Ayurvedic Institute

Albuquerque, NM

## Technical Expert Panel

We also wish to acknowledge the work of our technical expert panel. In addition to the four members who also acted as reviewers (see preceding page), the panel included the following individuals:

Betty L. Chang, DNSc, FNP-C, FAAN

Professor, School of Nursing, University of California, Los Angeles

Los Angeles, CA

Francesco Chiappelli, Ph.D.

Laboratory of Human Oral & Molecular

Immunology, School of Dentistry

University of California, Los Angeles

Los Angeles, CA

David Diehl, M.D.

Associate Clinical Professor of Medicine

Western Gastroenterologists, Inc

Irvine, CA

Seigward-Markus Elsas, M.D.

Clinical Fellow in Neurophysiology, University of California, Los Angeles

Los Angeles, CA

Glenn Clark, DDS

School of Dentistry

University of California, Los Angeles

Los Angeles, CA

Deborah Glik, Ph.D.

Associate Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Michael Goldstein, Ph.D.

Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Eric Hurwitz, D.C., Ph.D.

Assistant Professor, Department of Epidemiology, School of Public Health, University of California

Los Angeles, CA

Ka Kit Hui, M.D., FACP

Director, UCLA Center for East-West Medicine, University of California

Los Angeles, CA

Lucy Postolov, LAc

Postolova Acupuncture Group

Los Angeles, CA

David Riley, M.D.

Clinical Associate Professor, University of North West Medical School, Director, Integrative Medicine Research

Santa Fe, NM

George Solomon, M.D.

Professor Emeritus, UCLA School of Medicine, Dept. Psychiatry and Biobehavioral Medicine

University of California

Los Angeles, CA

Hitoshi Tomizawa, M.D.

Director, Japanese Executive Medical Services, Cedars-Sinai Medical Center

Los Angeles, CA

Xiao-Ping Xu, LAc

Burns and Allen Research Institute

Cedars Sinai Medical Center

Los Angeles CA

## Contacts in India

Dr. Swamy Venturupalli would also like to acknowledge and thank the following individuals:

M.S.Baghel, M.D. (Ay) Ph.D., WHO Fellow, I/C Reader- Kayachikitsa

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India

Dr. Chandola, M.D. (Ay)

I/C Reader- Kayachikitsa

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India

Dr. Kohli, M.D. (Ay)

Dept. of Kaya-Chikitsa

Podar Ayurvedic Medical College

Mumbai, India

Adarsh Kumar, M.D. (Ay)

Assistant Research Officer

Central Council for Research in Ayurveda and Siddha

New Delhi, India

D.K. Mishra, BAMS, M.D. (Ay)

Assistant Director (Ay)

Central Council for Research in Ayurveda and Siddha

New Delhi, India

Bibhas Ray, MS, Ph.D.

Consultant - Coordination and Liaison- Drug Development

Dr. Reddy's Research Foundation

New Delhi, India

V. Ravi Shankar, M.D. (Ay)

Assistant Director (Siddha)

Central Council for Research in Ayurveda and Siddha

New Delhi, India

Dr. Gurudeep Singh

Dean, Institute of Post Graduate teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India

Dr. Kulwant Singh

Department of Surgery

Institute of Post Graduate Teaching and Research in Ayurveda

Gujarat Ayurveda University, Jamnagar, Gujarat, India

G. Veluchamy, M.D. (Ay)

Director

Central Council for Research in Ayurveda and Siddha

New Delhi, India

A. Venkateshwarulu, Ph.D.

President- Research Division.

Dr. Reddy's Laboratories, Hyderabad, India.

R.S. Yadava

Assistant Director (Library)

Central Council for Research in Ayurveda and Siddha

New Delhi, India

## Others

Dr. Mary Hardy would also like to acknowledge and thank the following individuals:

Ruchi Mathur, M.D.

Endocronologist Fellow

Cedars Sinai Medical Center

Los Angeles, CA

Shannon Rhodes, MSA

Staff Assistant

Evidence-Based Practice Center

RAND

Santa Monica, CA

Nadia Khatib

Administrative Assistant

Evidence-based Practice Center

RAND

Santa Monica, CA

Jay Udani, M.D.

Los Angeles, CA