# Appendix L. Studies Not Included in Further Analysis

## Single Herbs

Marvah and Singh (1990) performed a case series evaluating the role of Cassia auriculata in NIDDM (type 2) patients. Patients were recruited from the outpatient clinic of the Gujarat Ayurvedic University, Jamnagar, India, and their diabetes was confirmed using the glucose tolerance test and other laboratory methods. An Ayurvedic evaluation of the patients' tridosha (the three bodily humors: vata, pitta, and kapha) was performed prior to and during the study. Patients with IDDM (type 1) and the sahaja and dhatukshyajanya types of madhumeha (Ayurvedic term for diabetes) were excluded from the study. Patients were told to eat their typical diet and were also given 5 g of Cassia auriculata powder three times a day for 2 months. Outcomes studied included clinical symptoms, the patients' doshas, GTT, FBS, lipid panel, urine glucose, and blood urea. Symptomatic relief was reported in 100 percent of the patients, all of whom were treated with Cassia auriculata. The effect on the GTT was significant; it showed a blood sugar reduction of 25.97 percent (p<0.05) in the second hour. Serum cholesterol was reduced by 8.42 percent (p<0.05) and blood urea by 12.67 percent (p<0.01). Study results are shown in Appendix Table 15.

Appendix Table 15. Study results for Marvah and Singh, 1990

Parameter (mg/dl) | Before treatment | After treatment | P value
Fasting glucose | 162.10 | 118.5 | <0.05
2-hour glucose | 254.91 | 188.70 | <0.001
Cholesterol | 282.79 | 258.98 | <0.05
Total lipids | 774.38 | 710.63 | <0.05
Blood urea | 29.2 | 25.5 | <0.01

Note: Standard deviation was not reported for each mean value.

The effect on the patients' tridosha was also reported. Highly significant (p<0.001) relief was found in the kapha- and pitta-dominant patients, with reductions of 89 percent and 73 percent of an unvalidated symptom score described by the authors. In their paper, the authors describe the action of Cassia auriculatain terms of Ayurvedic causality, but they do recommend its use in diabetic patients generally. Interpretation of these results is limited by the small numbers of patients and the subjective nature of the dosha assessment. The scale used by the authors could be useful if validated in larger groups of patients or if the dosha evaluations were performed by two independent examiners who reconciled any differences.

Sivaprakasam, Rao, Anandan, et al. (1985) studied the effects of Avarai elai (Cassia auriculata) and Koiiya elai (Psidium guajava, guava in English) on confirmed NIDDM (type 2) patients from the outpatient clinics of the Central Research Institute for Siddha and the Drug Research Scheme in India. Twenty-five patients were treated with Avarai elai (1 g, three times a day), and 20 patients were treated with Koiyya elai (1g, three times a day). Five patients dropped out of the Koiyya elai arm. Patients were instructed to follow the World Health Organization diabetic diet regimen and were instructed not to take any other hypoglycemic agents. Patients were treated for 24 months; however, there was no intent to treat analysis on patients who did not take the preparations for the full 24 months.

The researchers concluded that the formulations of Koiyya elai and Avarai elai at a dose of 1 g three times a day failed to show any significant reduction in blood glucose levels. There are numerous design flaws as noted above. The most significant of these was sample attrition, given the fact that less than 4 percent of the Avarai arm and 0 percent of the Koiyya arm remained in the study for the full 24 months. No adverse effects were reported from this study.

Chandola, Tripathi, and Udupa (1980b) reported the effects of Cinnamonum tamala on serum insulin levels and on fasting blood sugar in NIDDM (type 2) patients. The researchers identified a total of nine patients from the outpatient clinic at the Sunderlal Hospital in Varanasi, India, who had NIDDM confirmed with a glucose tolerance test. The researchers performed two separate studies measuring the effect of Cinnamonum tamala on fasting blood sugar and serum insulin levels. The first study involved five patients (20 percent female) who were given Cinnamonum tamala at a dose of 2 teaspoons four times a day for 15 days. The second study involved four patients who were given a single dose of Cinnamonum tamala (20 g) and were then followed for 4 hours. There were no comparison arms. Patients were asked to follow an 1,800-calorie diabetic diet during the study.

The preparation of Cinnamonum tamala leaves used in this study was a commercially available kitchen spice, called “Tej-patra,” which the researchers dried, pulverized, and filtered before giving it to the patients. There was no mention as to whether or not any patients were taking any concurrent allopathic medications for diabetes.

Patients in the 15-day study showed a statistically significant reduction in mean fasting blood sugar (56.6 mg/dl p<0.05) and a nonsignificant increase in plasma insulin levels (9.74 μU/ml p>0.05). Patients in the single-dose study (C. tamala given up to 2 hours before a GTT was done) also showed a significant reduction in mean fasting blood sugar (56.5 mg/dl p<0.05) as well as a significant increase in serum insulin levels (23 μU/ml p<0.05). No adverse effects were reported from this study.

The researchers concluded that Cinnamonum tamala has a positive effect on the release of insulin from the beta-cells of the islets of Langerhans. This conclusion was drawn solely from the results of the 2-hour study and was not corroborated by the15-day study performed by the same authors.

Chandola, Tripathi, and Udupa (1980a) performed a series of three studies with type 2 diabetic patients to study the hypoglycemic effects of Cinnamonum tamala. The article is discussed in Chapter 3 under the heading “Controlled Clinical Trials” because the first of the three studies is a CCT.

Chaturvedi, Subramaniyam, Tiwari, et al. (1983) conducted a series of case studies evaluating the oral hypoglycemic effect of Arani, an Ayurvedic drug prepared from the plant Clerodendron philomidis. The patients were recruited from the SS Hospital, Varanasi, India. Demographics, including age, gender, and inclusion/exclusion criteria were not described for this study. The diagnostic criteria were fasting blood sugar and urine glucose.

Thirteen patients were treated with Arani as a crude drug decoction (1:4 concentration) of Clerodendron phlomidis; 15 to 30 g daily was given in divided doses for an average of 5.2 weeks. Tolbutamide (500 mg/day) was given to three diabetic patients for 2 weeks. Three patients were given 30 units of insulin for 2.3 weeks. Four patients on diet only were followed for an unknown period. A marked improvement in symptoms was observed in the Arani-treated arm. Urine became free of sugar in 46 percent of patients (no p value given). Also a marked reduction in blood sugar values, from 202 mg/dl to 149 mg/dl was reported. A drop of urine sugar, from 2.2 mg/dl to 0.8 mg/dl, was also noted. No statistical tests were performed and the article does not report sufficient data for re-analysis.

Observations in this study showed a fall in blood sugar and urine sugar along with symptomatic improvement, but the lack of specific data (no means, no standard deviations) and the small number of patients in the multiple arms of the study make generalization difficult.

Nande, Kale, and Wagh (1983) studied of the effects of the Jambu fruit (Eugenia jambolana) on the blood sugar levels of seven healthy volunteers and five diabetic patients. The seven healthy volunteers were in Arm I (23–34 years old, 0 percent female). The five diabetic patients (25–70 years old, 60 percent female) were in Arm II. All the subjects were given 150 g of fresh Jambu fruit and asked to eat only the pulp. The remaining seeds were collected and weighed to determine the quantity of pulp consumed, which averaged 114 g (range 107–120 g) per person. One patient in the non-diabetic arm consumed 184 g of pulp and was excluded from analysis. Blood sugar was measured at baseline and at 1 hour, 2 hours, and 3 hours.

Study results are shown in Appendix Table 16. There was a small but statistically significant drop in the blood sugar levels in the non-diabetic patients (p< 0.05). In the diabetic patients, there was a small increase in blood sugar levels. However, this increase was not statistically significant, and the actual values were not reported.

Appendix Table 16. Study results for Nande, Kale, and Wagh, 1983

Patients | Average quantity of pulp consumed | Mean fasting blood sugar (mg/dl) ± (SE) | Mean 3-hour blood sugar (mg/dl) ± (SE)
Arm I (healthy) | 115.2 g | 75.3 ± 2.63 | 68.3 ± 2.11
Arm II (diabetic) | 112.1 g | 240 ± 44.3 | 272 ± 49.67

SE=standard error

The authors concluded that Jambu fruit does not seem to have a significant role in the management of diabetes. The small number of patients, the use of just one dose of the fruit, and the nonreporting of actual data are the limitations of this study.

Sepaha and Bose (1956) studied the effects of Pterocarpus marsupium and Eugenia jambolana on 21 type 1 diabetic patients (9.5 percent female, 20 to 60 years old). Patients were selected from those admitted to the medical ward at the Medical College of Indore, India, and did not have end-stage diabetes or diabetic complications. Patients were put on an 1,800-calorie American Diabetes Association (ADA)-recommended diet and observed for 5 days without insulin before beginning treatment.

Arm I (n=17) patients were given 1 oz of an aqueous or alcoholic extract of Pterocarpus marsupium three times a day. Three patients were followed for less than 7 days, and their data were not included in the study. No significant reduction in blood sugar level was observed. Adverse effects including albuminuria, acetonuria, and an increase in serum glucose levels were noted in Arm I patients. Arm II (n=7) patients were given 1 dram of Eugenia jambolana three times a day for at least 10 days. A number of patients continued for 20 days with three patients continuing for up to 70 days. Five of the patients enrolled in Arm II were patients who had failed to achieve glycemic control during Arm I using the Pterocarpus marsupium treatment. Of the seven patients in Arm II, three patients showed a reduction in blood glucose levels and in urine glucose levels, but no statistical significance was observed. No adverse effects were reported in Arm II patients.

The researchers were encouraged by a nonsignificant reduction in serum glucose levels in 7 percent of the Pterocarpus patients and in 42 percent of the Eugenia patients. However, the absence of statistical significance in such a small sampling of patients makes it impossible to share the authors' enthusiasm for these two study drugs. Given the small sample size, the failure to include the three dropouts in the analysis (i.e., no intention to treat analysis was done) further limits the conclusions that can be drawn from these data. In addition, most of Arm II was composed of treatment failures from Arm I. Presumably, this is a more treatment-resistant group and may not represent a fair assessment of the second herb (Eugenia jambolana) used. A followup study with randomization, blinding, a larger sample size, and a single study drug compared with placebo are essential for any conclusions to be drawn.

Raghuram, Sharma, Sivakumar, et al. (1994), in an RCT, studied the effects of fenugreek seeds in 10 NIDDM (type 2) patients at the National Institute of Nutrition, Hyderabad, India. All patients (ages 38 to 54 years, percent female not reported) were taking glibenclamide during the study. They were randomly assigned to receive a placebo diet or a fenugreek-enriched diet for 15 days each in a crossover design trial. (This study was not included in Evidence Table 1 because the duration was less than 30 days.) During both of these study periods, patients received their entire diet from the institute. The fat and protein content of the control diet was equalized to that of the experimental diet by the addition of peanut isolate. There was no blinding of either the patients or the researchers.

Patients were given powdered fenugreek seeds (25 g per day) incorporated into unleavened bread served during lunch and dinner. Both the control and experimental diets were identical except for the protein and fiber content, which was significantly higher in the experimental diet. No adverse effects were observed.

The researchers reported a statistically significant reduction in blood glucose levels at 40, 50, and 60 minutes after a glucose load (p<0.02). The actual values are not reported. Additionally, they reported a significant decrease in the serum glucose area under the curve (AUC) (p<0.05) and in the glucose half-life (p<0.02), as well as significant increases in the serum glucose metabolic clearance rate (p<0.02) and in glucose erythrocyte insulin receptors (p<0.02).

The researchers concluded that the addition of 25 g of fenugreek seed to the daily diet of NIDDM (type 2) patients can be an effective supportive therapy in the management of diabetes. Additionally, they propose that fenugreek may modulate plasma glucose levels by delaying gastric emptying, by direct interference with glucose absorption, and by systemic effects as indicated by the statistically significant reduction in AUC, half-life, metabolic clearance rate, and erythrocyte insulin receptors. The study's design flaws make it difficult to support such a statement. However, this study suggests that the use of fenugreek seed in the management of NIDDM (type 2) patients merits further investigation. The Jadad score for this trial is 1.

Sharma and Raghuram (1990), in an RCT, studied the effects of a diet enriched with fenugreek seeds on NIDDM (type 2) patients at the National Institute of Nutrition, Hyderabad, India, using a randomized, crossover design in two trials. The first arm consisted of 15 patients randomized to receive a fenugreek-enriched diet either during the first 10 days of the trial or during the second 10 days. These patients (33 percent female, ages 32 to 60) had diabetes from 2 months to 16 years. The second arm consisted of five NIDDM (type 2) patients (ages 35 to 58) who were also randomized to receive a fenugreek-enriched diet for either the first or second 20 days of the trial. Gender and other demographic data were not reported for the second arm. Patients not on the intervention diet were instructed to eat a control diet. The two diets were nutritionally identical, except the protein and fiber content was significantly higher in the experimental diet. During both of these trials, patients received their entire diet from the institute. There was no blinding of either the patients or the researchers. It was not noted whether or not the study patients were taking any concurrent allopathic medications. The experimental diet contained defatted fenugreek seed powder (100 g per day) incorporated into unleavened bread served during lunch and dinner. A protein isolate from groundnut was added to the control diet to supplement the protein content.

Patients given the intervention diet in the first arm had a statistically significant reduction in mean fasting blood sugar of 42 mg/dl (p<0.05). Their mean serum insulin level dropped 17.6 μU/l (p<0.05), a significant reduction, and their mean 2-hour post-prandial blood glucose dropped by 110 mg/dl (p<0.01). The mean urinary glucose excretion was reduced by 64 percent (p<0.05). There was also a significant reduction of 29 mg/dl (p<0.001) in total serum cholesterol and of 23 mg/dl (p<0.001) in low-density lipoprotein (LDL) and very low-density lipoprotein (VLDL) cholesterol.

Patients given the experimental diet in the second arm showed a significant decrease in mean fasting blood glucose of 41 mg/dl (p<0.05) as well as significant reductions in 24-hour urinary glucose excretion, serum cholesterol, and triglyceride levels (p<0.05). No adverse effects were reported in either arm.

The researchers concluded that the addition of 100 g of fenugreek seeds to the daily diet of NIDDM (type 2) patients could be effective supportive therapy in the prevention and management of long-term complications of diabetes. The results suggest that the use of fenugreek seed in the management of NIDDM (type 2) patients merits further investigation. (The study was not included in Evidence Table 1 because it did not meet the criteria outlined; see Chapter 3.) The Jadad score for this trial was 2.

Sharma, Raghuram, and Rao (1990), in an RCT, studied the effects of a diet enriched with fenugreek seeds on 10 IDDM (type 1) patients at the National Institute of Nutrition, Hyderabad, India. These patients (33 percent female, 12 to 37 years old) were on continuous insulin therapy. They were kept in the hospital on a fixed insulin dose for the duration of two 10-day trial periods. Patients were randomized to receive either the fenugreek-enriched diet or a control diet for the first 10-day period, after which they switched diets for another 10-day period. (This study was not included in Evidence Table 1 because the duration was too short.)

The experimental diet contained defatted fenugreek seed powder (100 g per day) incorporated into unleavened bread served during lunch and dinner. A protein isolate from groundnut was added to the control diet to adjust the protein content. Both the control diet and the experimental diet were identical except for the fiber content, which was significantly higher in the experimental diet. The patients were not told when they were on the experimental diet or the control diet.

Four patients complained of minor gastrointestinal irritation (diarrhea, excess flatus) while on the fenugreek diet, but no other adverse effects were reported.

On the experimental diet, patients had a statistically significant reduction of 84 mg/dl (p<0.01) in mean FBS and 94 mg/dl (p<0.055) in the 1½-hour PPBS. There was no significant reduction in the serum insulin levels. The mean urinary glucose excretion was reduced by 54 percent (p<0.01). There was also a significant reduction in total serum cholesterol (p<0.001) and in LDL and VLDL cholesterol (p<0.01).

The researchers concluded that the addition of 100 g of fenugreek seeds to the daily diet of IDDM (type 1) patients can be an effective supportive therapy by improving glucose tolerance and the serum lipid profile. In addition, the crossover design did not incorporate a wash-out period for both arms, which may have affected the results observed in the second trial period. However, this study does suggest that the use of fenugreek seed in the management of IDDM (type 1) patients merits further investigation. This trial had a Jadad score of 1.

Sharma, Sarkar, Hazra, et al. (1996b) conducted a case series evaluating fenugreek on patients with NIDDM. Patients were recruited from the diabetes clinics of S. N. Medical College, Agra, India. There were 60 patients, 25 percent female, with an age range from 30 to 70 years. Inclusion/exclusion criteria were not described. Diagnostic criteria included fasting blood sugar and glucose tolerance test. Twenty-two patients had mild diabetes, 31 had moderate diabetes, and 7 had severe diabetes. Of the 60 patients, 40 took oral hypoglycemic agents. Each subject underwent two test periods. There was one control period during which patients were given isocaloric diets without fenugreek for 7 days. This was followed by a study period of 24 weeks when patients were given the same diets along with fenugreek seeds powdered and made into a soup with water. The dose was 12.5 g of fenugreek twice a day.

As shown in Appendix Table 17, results indicate a potential beneficial effect from fenugreek seeds for diabetic patients. The use of a concurrent diet therapy is a limitation of this study.

Appendix Table 17. Study results for Sharma, Sarkar, Hazra, et al., 1996b

Values | Cholesterol (mg/dl) | LDL (mg/dl) | HDL (mg/dl) | LDL + VLDL (mg/dl) | Triglycerides (mg/dl)
Basal (end of control period) | 241 | 143 | 54 | 179 | 187
24 weeks | 199 | 114 | 60 | 148 | 159
P value | <0.001 | <0.001 | NS | <0.001 | <0.001

LDL=low-density lipoprotein; VLDL=very low-density lipoprotein

Sharma (1986) performed a series of pre/post studies looking at the effect of fenugreek on serum glucose and insulin levels. Demographics (age and gender), recruitment, inclusion and exclusion criteria, and diagnostic criteria of the study group were not given.

Six protocols to test the acute effects of fenugreek were performed. These protocols involved administering various preparations of fenugreek seeds to healthy subjects. Whole fenugreek seeds, extracted fenugreek seed powder, gum isolate from fenugreek seed, degummed fenugreek seed, cooked fenugreek seed, and cooked fenugreek leaves were all tested. Outcomes studied were blood glucose and insulin levels. The gum isolate of fenugreek significantly reduced plasma glucose at 30 and 60 minutes (p<0.05), and it significantly altered the serum insulin levels at 30 minutes (p<0.01) and at 60 minutes (p<0.05). The other preparations did show a consistent reduction in plasma glucose with serum insulin.

After a 2-week period to stabilize the diet, defatted fenugreek seeds were also administered to five diabetic patients for 21 days at a dose of 25 g twice a day with meals. At the end of the study period, a standard glucose tolerance test was performed on all subjects. Lipid levels were also measured. The results are summarized in Appendix Table 18.

The author believed that fenugreek exerted both acute and chronic effects on blood glucose. The herb produced lower insulin and glucose responses to the standard glucose tolerance test load following a single dose of the herb. The author judged this effect to be the result of the fiber content of the fenugreek. Chronic administration of fenugreek was useful in lowering both blood sugar and cholesterol. The anti-diabetic effects of fenugreek were not destroyed by cooking; and consequently the author felt that this herb would be a useful addition to a diabetic diet.

Appendix Table 18. Study results, after 3 weeks, for Sharma, 1986

Parameter | Before treatment | After treatment | P value
Fasting glucose | 128.8 ± 18.9 | 102.8 ± 18.9 | <0.05
2-hour post-prandial blood sugar | 247.6 ± 54.7 | 191.6 ± 35.2 | <0.05
Cholesterol | 231 ± 23.6 | 204 ± 18.5 | <0.05

Smith and Holm (1982) enrolled a series of healthy and diabetic patients in a study to test the effect of gum guar on serum glucose and lipid levels. Seventeen diabetic patients (6 insulin dependent and 11 on oral hypoglycemic medication, ages 22–73 years) were recruited along with 6 healthy volunteers (ages 20–40 years, 67 percent female) from a Western mainstream practice in Sweden. Diagnosis of diabetes was confirmed by fasting blood sugar. The demographics of the study group were not given nor were inclusion/exclusion criteria described.

A standard meal to be eaten at home was provided to all patients. They were instructed to take 10 g of granulated guar gum stirred in 50 ml of water prior to meals twice a day for 1 or 3 weeks, and in some cases up to 13 weeks. The average duration of administration was 3 weeks. The authors noted that the granulated layer of the guar gum solution is fairly rapidly dissolved in liquid, thus producing a highly viscous product in the stomach, which seems necessary for its effect.

The authors reported that there were statistically significant decreases in the fasting blood sugar and post-prandial blood sugar for all diabetic patients (p<0.05). However, the actual glucose levels were not reported. The serum cholesterol decreased from 5.46 mM to 4.68 mM (p<0.005). The serum triglycerides were not significantly lowered.

The most frequent side effects were increased flatulence and occasional abdominal cramps. Two of the insulin-dependent patients had more frequent hypoglycemic episodes, and their insulin was lowered by 4 to 8 units/day. The authors concluded that guar gum leads to lowering of fasting and post-prandial blood sugars as well as serum cholesterol levels, with minimal side effects. Thus, they believed that guar gum represents an interesting and possibly beneficial fiber supplement for diabetic patients.

Balasubramaniam, Arasaratnam, Seevaratnam, et al. (1988) studied the effects of Gymnema sylvestre on eight NIDDM (type 2) patients. No age, gender, or other information was available for these patients. There was no mention of concurrent hypoglycemic agents, nor was there any blinding or controls for this study.

Patients were given 10 g of Gymnema sylvestre leaf powder taken orally once a day for 21 days.

At the end of treatment, the patients showed a statistically significant 50.5 mg/dl reduction in mean fasting blood glucose and a 74.2 mg/dl reduction in mean 2-hour blood glucose levels (p<0.05) compared to baseline. The study also found a nonsignificant increase in mean body weight (0.9 kg) during this same 21-day period. No adverse effects were reported, and serum glutamic pyruvic transaminase (SGPT) levels were described as being within the normal range for all patients after treatment.

The researchers concluded that Gymnema sylvestre has a hypoglycemic effect by reducing the fasting glucose levels as well as the 2-hour blood glucose levels. The authors added that further studies should be undertaken to confirm these results and to determine the herb's mechanism of action. Such studies will benefit from the addition of blinding, randomization, and a larger patient pool, as well as a comparison arm.

Kothe and Uppal (1997) studied the effects of a homeopathic preparation of Gymnema sylvestre on 21 diabetic patients. The patients (ages 36–74 years, 33 percent female) included 7 patients with diabetic complications and 14 patients without complications. The study's inclusion/exclusion criteria, demographics, and diagnostic criteria were not described. The test drug, Gymnema sylvestre Q (mother tincture), was given in the following doses: 6 to 7 drops twice a day for patients with FBS of 80–100 mg/dl and PPBS of 160–180 mg/dl; 10 drops three times a day for patients with FBS of 100–120 mg/dl and PPBS of 180–200 mg/dl; and 15 drops four times a day for patients with FBS of 120 mg/dl and greater and PPBS of 200 and greater. Suitable homeopathic remedies were also prescribed for patients with complications.

The study was carried out for 6 months. No quantitative results were reported. The authors state that out of the seven patients with complications, three showed excellent results in controlling blood sugar, two showed moderate control, and two remained uncontrolled. Of the patients without complications (n=14), nine responded well, two showed moderate control, and three remained uncontrolled. The nonreporting of any quantitative data, lack of control, small number of cases, and the unspecified variations in dosage are serious design flaws of this study.

Balasubramaniam, Arasaratnam, Nageswaran, et al. (1992), in a CCT, studied the effects of Gymnema sylvestre on the fasting and post-prandial blood sugar of 16 normal subjects and 43 type 2 diabetic patients. The subjects' ages ranged from 43 to 68 years; gender and socioeconomic status of the patients were not mentioned, nor were the inclusion and exclusion criteria. All the patients received powdered leaf extract of Gymnemra sylvestre at a dose of 10 g/day for 7 days. Arm I consisted of the normal patients (n=16), who did not receive any treatment other than the initial one. The 43 diabetic patients, divided between Arm II and Arm III, did receive further treatment. Arm II (n=7) received Gymnema sylvestre powder for an additional 14 days, and Arm III (n=36) received an oral hypoglycemic agent (Tolbutamide) for an additional 7 days but no more Gymnema sylvestre.

Results were reported as follows. In Arm II there was a reduction in FBS level from 151.7 mg/dl to 101.2 mg/dl at 21 days and a reduction in PPBS level from 215.7 mg/dl to 141.5 mg/dl at 21 days. Both these changes were statistically significant (p values were not reported). In Arm III, there was a decrease in FBS from 157.8 mg/dl to 136.3 mg/dl at 7 days, and the FBS continued to be low (133.1 mg/dl) on day 14. The PPBS decreased from 244.8 mg/dl to 144.7 mg/dl at day 7 and was 135.5 mg/dl at day 14. The difference in FBS and PPBS from day 1 to day 7 was statistically significant, as was the difference from day 1 to day 14. There was no significant change from day 7 to day 14. In the arm of normal patients (Arm I), the FBS changed from 80.8 mg/dl to 71.6 mg/dl at day 7. This change was statistically significant.

Results for cholesterol are shown in Appendix Table 19. These differences were statistically significant for Arms II and III, but not for Arm I. The authors did not detect any short-term toxicity from the test drug.

The authors concluded that Gymnema sylvestre leaf powder has a definite hypoglycemic effect in both normal and diabetic patients. They further concluded—based on the differences from day 7 to day 14 in FBS and PPBS values between Arm II and Arm III—that Gymnema sylvestre was at least as effective as oral hypoglycemic agents. The short duration arm is a weakness of this study. The Jadad score was 0.

Appendix Table 19. Study results (effects on cholesterol), Balasubramaniam, Arasaratnam, Nageswaran, et al., 1992

| Arm II and III (diabetic patients) | | Arm I (normal patients)
| Day 0 | Day 7 | Day 0 | Day 7
Triacylglycerol (m mol/L) | 1.63 | 1.36 | 1.4 | 1.4
Free fatty acids (μmol/L) | 1.12 | 0.8 | 0.7 | 0.67
Cholesterol (mg/dl) | 284.2 | 244.3 | 216.7 | 199.9

Khare, Tondon, and Tewari (1983) published a report of the hypoglycemic effects of Gymnema sylvestre leaves on diabetic and normal healthy adults. Arm I (n=10, 40 percent female, ages 19–25 years) consisted of healthy student volunteers with no diabetes who were recruited from G. S. V. M. Medical College, Kanpur, India. Arm II (n=6, 33 percent female, ages 35–50 years) consisted of type 2 diabetic patients who were recruited from the diabetic clinics of L. L. R. and associated hospitals in Kanpur, India. The diabetic patients were identified as having mild-to-moderate hyperglycemia without any diabetic complications. No mention of socioeconomic characteristics or demographics or clinical equivalence between the arms was made. The patients were given an aqueous decoction of the shade-dried leaves of Gymnema sylvestre in a dose of 2 g three times a day. Subjects in Arm I received the preparation for 10 days, and subjects in Arm II for 15 days.

Study results are shown in Appendix Table 20. The authors concluded that Gymnema sylvestre demonstrated a hypoglycemic effect both in normal and diabetic subjects. The small number of subjects and the short duration of the study are drawbacks of the study, along with the lack of a placebo comparison arm and random allocation.

Appendix Table 20. Study results for Khare, Tondon, and Tewari, 1983

Subjects | Time | Fasting blood sugar (mg/dl) | 30-minute post-prandial blood sugar (mg/dl) | 2-hour post-prandial blood sugar (mg/dl)
Arm I | Initial | 80.2 | 155.1 | 76.7
| 10 days | 69.2 (p<0.05) | 132.2 | 66.8
Arm II | Initial | 135.7 | 220 | 152.7
| 10 days | 110.7 (p<0.02) | 180.7 (p<0.05) | 121.1 (p<0.01)

Akhtar (1982) studied the effects of karela (the fruit of Momordica charantia) on eight patients with uncomplicated NIDDM (type 2). Patients (50 percent female, ages 38 to 50 years) were randomly recruited from the outpatient clinic at Agriculture University Hospital, Punjab, India. All anti-diabetic medications were stopped 48 hours prior to the initiation of the study, and all patients were placed on a low-carbohydrate diabetic diet.

Patients were given 50 mg/kg of body weight of powdered karela obtained from a local vegetable market, twice a day for 7 days. There was no blinding of either the patients or the researchers.

The study showed a statistically significant 100 percent (p<0.001) reduction in the mean urinary excretion of glucose. There was also a significant decrease of 93 mg/dl (p<0.001) in mean fasting glucose levels and 130 mg/dl (p<0.001) in mean 2-hour post-prandial glucose levels. No adverse effects were reported.

The researchers concluded that karela produced significant reductions in hyperglycemia and could be recommended for the oral treatment of patients with uncomplicated NIDDM (type 2). They also concluded that clinical studies on a larger scale are needed to further establish karela's antidiabetic efficacy.

Baldwa, Bhandari, Pangaria, et al. (1977), in a controlled trial, studied an insulin-like protein compound obtained from Momordica charantia. Eight male and one female diabetic patients (ages 16–52) were recruited from S. M. S. Medical College, Jaipur, India. The duration of diabetes ranged from 3 months to 10 years. Five healthy controls were also included in the study. A comparison arm of diabetic patients (n=5) was included as well. Diagnosis of diabetes, both IDDM (type 1) and NIDDM (type 2), was confirmed by clinical exam and glucose tolerance test. No further inclusion criteria were given. All subjects were given injections of either the vegetable insulin product or placebo, and an extended glucose tolerance test was performed. The dose was adjusted based on blood sugar as described in Appendix Table 21.

Appendix Table 21. Dosage of vegetable insulin based on blood sugar, Baldwa, Bhandari, Pangaria, et al., 1977

Severity of diabetes | FBS level (mg/dl) | Dose of vegetable insulin
Mild | <180 | 10 units
Moderate | 180–250 | 20 units
Severe | >250 | 30 units

FBS=fasting blood sugar

Placebo injection in the comparison arm (normal and diabetic) produced no change in blood sugar levels. The vegetable insulin produced an insulin-like effect. This peaked after 4 hours in six juvenile diabetic patients; after 6 hours in two patients with adult-onset diabetes; and after 12 hours in one patient with maturity-onset diabetes. (Note: The authors made a distinction between adult-onset and maturity-onset diabetes when conventionally they are the same.) All values in this study were analyzed statistically by applying the paired t-test. The average fall in blood sugar at the peak effect of the vegetable insulin was statistically significant. Results are shown inAppendix Table 22.

Appendix Table 22. Fall in blood sugar, Baldwa, Bhandari, Pangaria, et al., 1977

Clinical arms | Percent fall in blood sugar
| FBS (mg/dl) (SD) | 1-hour PPBS (mg/dl) (SD) | 4-hour PPBS (mg/dl) (SD) | 8-hour PPBS (mg/dl) (SD)
Healthy controls (n=5) | 75 (7.4) | 5.0 (1.7) | 5.4 (1.8) | 5.5 (1.4)
Diabetic controls (n=5) | 210 (11.8) | 4.5 (2.6) | 5.8 (1.8) | 5.8 (1.8)
Diabetic treatment (n=9) | 295 (15.7) | 24.8 (11.0) | 49.2 (13.7) | 35.9 (10.3)

FBS=fasting blood sugar; PPBS=post-prandial blood sugar; SD=standard deviation

This novel insulin product demonstrated a consistent hypoglycemic action in a small number of diabetic patients. It had a pharmacokinetic pattern between regular and NPH types of insulin. No adverse events were recorded. The authors suggested that this product had possible value when animal insulin cannot be used. The advent of recombinant insulin, however, places the utility of this observation in some doubt, except possibly in countries where recombinant insulin is prohibitively expensive. The Jadad score for this trial was 1.

Leatherdale, Panesar, Singh, et al. (1981) studied the effects of karela (the fruit of Momordica charantia, which is indigenous to South America and Asia) on glucose and insulin concentrations in nine NIDDM (type 2) patients (33 percent female, age not reported). The patients were taking various allopathic hypoglycemic agents, including chlorpropamide, tolbutamide, glibencalmide, and glymidine. They were given three oral glucose tolerance tests: one at the beginning of the study; one immediately after taking 50 ml of karela juice; and a final test 8 to 11 weeks after eating 0.23 kg of fried karela daily. Patients were instructed to stop their hypoglycemic agents for 48 hours before each test.

For the juice test, patients were given 250 ml of fresh squeezed juice concentrated by rotary evaporation. For the fried karela test, patients were given slices of karela (0.23 g/day) and instructed to fry them in vegetable oil. No other dietary restrictions were imposed.

Patients showed a significant reduction in plasma glucose levels during the glucose tolerance test at 30 minutes (p<0.05), at 60 minutes (p<0.01), and at 90 minutes (p<0.001) compared with controls. When the results of this first test were reported, the glucose values themselves were not given; only the area under the curve of the glucose tolerance test was reported. In the second study, patients who ate fried karela also showed a statistically significant 1.7 percent (p<0.01) reduction in glycosylated hemoglobin compared to pre-study levels. Additionally, insulin concentrations were statistically higher by 6.7 μU/l (p<0.05) when the patients were given karela juice compared to pre-study levels. Interestingly, insulin levels were significantly lower by 32.9 μU/l (p<0.05) after patients ate fried karela for 8 to 11 weeks. No adverse effects were reported.

The researchers concluded that karela, taken as both a juice extract and as a dietary supplement in a fried form, has a significant hypoglycemic effect that does not appear to be a result of hyper-insulinemia. The study was weakened by the fact that hypoglycemic medications were removed for only 48 hours prior to each test; however, it does demonstrate that karela causes a significant reduction in hyperglycemic response following a glucose load. This plant merits further study.

Welihinda, Karunanayake, Sheriff (1986) studied the effects of Momordica charantia on 18 new-onset NIDDM (type 2) patients (percent female not reported, average age 38.2 years) who were free from any diabetic complications and were not taking any concurrent hypoglycemic agents.

A standard oral glucose tolerance test (50 g glucose load in 100 ml distilled water) was performed on all patients after an overnight fast. The test was repeated the next day with all patients receiving 100 ml of Momordica charantia juice 30 minutes before the oral glucose load. The juice was made from fresh unripe fruits of M. charantia obtained from the local market. All of the juice was extracted at the same time, and this fresh juice was frozen. As needed, the appropriate amounts were thawed, the supernatant was decanted, and 100 ml aliquots of clear juice were given orally to the patients.

Glucose tolerance curves were obtained after all 18 patients ingested the M. charantia juice. These were then compared to the corresponding curves after the patients drank water. This analysis revealed that 13 patients showed a significant improvement in glucose tolerance, and 5 patients showed no improvement. The mean total area (187.0 cm^2^) under the juice-test glucose tolerance curves was significantly smaller than the area (243.6 cm^2^) under the water-test curves, which served as controls (p<0.001).

The researchers concluded that M. charantia has hypoglycemic activity. The failure to measure fasting blood glucose levels make this study inconclusive.

Srivastava, Venkatakrishna-Bhatt, Verma, et al. (1993) reported a case series evaluating the properties of Momordica charantia extract (powder vs. aqueous extract) on glucose levels of diabetic patients. Glucose tolerance tests confirmed the diagnosis of diabetes, and all participants maintained a diabetic diet. The first set of diabetic patients (n=5) was given a powder of dried Momordica charantia fruit (the plant is also known as bitter melon) at a dose of 5 g three times per day for 3 weeks. The patients treated with the powdered form of Momordica charantia showed a trend toward lowered blood glucose levels, but this did not reach statistical significance. An aqueous extract from Momordica charantia was obtained by boiling 100 g of fruit in 200 ml of water. It was given to a second set of diabetic patients (n=7, all male, ages 42–70) at a dose of 100 ml once per day for 3 weeks. The subjects treated with the aqueous extract showed a significant decrease in the hemoglobin A_1c_ from 8.37 percent to 6.95 percent (p<0.01). The absence of female participants limit the ability to generalize from this data.

Srividya and Periwal (1995) reported a study of the effects of Phyllanthus amarus 6 on blood glucose in 14 patients. The patients were recruited from the clinics of local physicians in Anantpur, India. Their ages ranged from 40 to 60 years, and the arm was 56 percent female. Socioeconomic characteristics of the patients and inclusion/exclusion criteria were not reported. The patients were classified into three arms: Arm I consisted of five normal control subjects; Arm II consisted of five hypertensive patients; and Arm III consisted of four patients with diabetes and hypertension. The patients in Arm II and III received Phyllanthus amarus (powdered whole plant) at a dose of 1.6 g three times a day with meals for 10 days.

Also known as Phyllanthus niruri.

Results were reported as follows. Mean fasting blood sugar in Arm II and Arm III patients decreased from 126.4 to 109.4 mg/dl (p<0.001). The authors concluded that Phyllanthus amarus has definite potential as a hypoglycemic drug for humans, with no side effects.

Mathew and Augusti (1975) studied the effects of onion (Allium cepa) on three NIDDM (type 2) patients (33 percent female, ages 45 to 62). No other socioeconomic or demographic data were reported. Patients were instructed to stop taking their allopathic hypoglycemic agents 5 days prior to initiating onion therapy.

After the patients had followed a standardized diet for 7 days, they were given 50 g of juice-expressed onion residue. The onion was prepared by drying 100 g of fresh onion in the sun and then powdering the resulting dried material. That powder was then extracted with ether, and the extracted fraction was again dried to a powder. A further extraction was done with petroleum, and the petroleum-insoluble fractions, once dried, were administered to the patients along with a standardized diet for 1 week. At the end of the study, glucose tolerance tests were performed.

The authors reported that the study patients had a rise in blood sugar of 75 to 90 mg/dl before the onion intervention but only 25 to 50 mg/dl after onion was used. Moreover, the blood sugar values came down to normal after 4 hours when onion was used. This was not the case when onion was not used. No adverse effects were reported from this study.

The researchers concluded that the common onion may contain hypoglycemic properties.

Sharma, Gupta, Gupta, et al. (1977) studied the effects of an aqueous extract of onion on 20 healthy volunteers (10 percent female, ages 20 to 30 years) at the Medical College of Jhansi, India. The volunteers were subjected to five interventions that compared different concentrations of the onion extract. These patients were also compared to patients receiving tolbutamide. In a separate study, the researchers also studied the effects of onion on glucose tolerance tests in patients with and without adrenaline-induced hyperglycemia.

The water-based extract used in the studies was prepared from locally bought onions that were blended into a pulp and then filtered twice. The volume of the final filtrate was corrected by the addition of distilled water so that 1 ml of extract represented 1 g of onion by weight. Patients were given between 25 and 200 g of this aqueous onion extract.

Aqueous extract of onion did not produce a change in fasting blood sugar in normal volunteers, even with doses that increased from 25 g to 200 g. However, the authors also reported that when onion extract was administered in various doses along with 50 g of glucose during an oral glucose tolerance test, it reduced the normal rise in glucose in a dose-dependent manner. The study showed no effect of onion on fasting blood glucose levels. The blood sugar lowering effect of various doses of onion extract was reported to be statistically significant (p<0.05 to <0.01), and at the highest doses of onion, it was comparable to the effect of tolbutamide.

The researchers concluded that aqueous onion extract has an anti-hyperglycemic, as opposed to a hypoglycemic, effect on healthy volunteers. They based this conclusion on the observation that the main effect of the onion extract was not on fasting blood glucose but on the rise in glucose following a glucose load. They also reported that the active principle in the onion is not degraded by heat because boiling the onion extract did not change its anti-hyperglycemic effect. As a preliminary investigation of onion as a possible anti-hyperglycemic agent, this study presents dose-response curves and elucidates some potentially useful areas for additional research.

Rajasekharan and Tuli (1976) studied the effects of vijaysar (Pterocarpus marsupium) on 35 patients with NIDDM (type 2) (40 percent female, ages 20 to 60+ years). It is unknown if these patients were taking any concurrent allopathic medications.

Vijaysar is made from the heartwood of Pterocarpus marsupium, which is decocted in water and then dried into a powder. Patients were given varying doses of 250 mg capsules of vijaysar depending on their age, stamina, and what the authors describe as “intensity of disease” for 1 month.

The majority of patients reported good to fair improvement in symptoms of polyphagia, polydipsia, and polyuria. Out of 23 patients for whom blood sugar levels were reported, only 8 showed a good to fair response in reducing blood glucose. The mean values and statistical tests were not reported. The study reported reductions in blood glucose levels, urinary glucose excretion, and symptoms of polyuria, polydipsia, and polyphagia. No adverse effects were reported.

The researchers concluded that vijaysar had an anti-diabetic effect on the treated patients. The lack of statistical analysis makes it impossible to draw conclusions from this study. Further investigation is needed to assess the anti-diabetic effects of vijaysar.

## Combinations and Formulas

Shankar and Aggarwal (1988) studied the effects of Abraga Chendooram on 60 patients with NIDDM (type 2). Patients were selected from the diabetes clinic at Safdarjang Hospital in New Delhi, India. Potential participants were given a glucose tolerance test to confirm diagnosis and were then treated with dietary control for 15 days. Only those patients (n=60, ages 21–70 years, 45 percent female) who failed dietary control and who did not show evidence of serious complications of diabetes (ketoacidosis, nephropathy, neuropathy, or retinopathy) were eligible for the study.

Patients were given a formula called Abraga Chendooram that consisted of Abragam (purified black mica); Vengaram (dehydrated borax); Saranaiver Charu (juice of the root of Trianthema decandra); Adathondaielai Charu (juice of the leaves of Adhatoda zeylanica); and Alam vizhuthu kudineer (root of Ficus benghalensis). Patients were given 200 mg of the drug in gelatin capsules twice daily for 45 days. During this period, caloric intake was restricted to 25 calories per kg of ideal body weight. No mention was made of whether or not any patients were taking any concurrent allopathic medications for diabetes.

This study did not provide information on the actual fasting blood sugar results. Instead, patients were categorized into “complete relief” (normal blood sugar levels), “partial relief” (blood sugar levels slightly above normal; no actual range given), and “no relief” (no change in blood sugar levels). At 45 days, 35 patients (59 percent) demonstrated complete relief; 20 (33 percent) demonstrated partial relief; and 5 (8 percent) showed no relief. No adverse effects were reported from this study.

The researchers concluded that Abraga Chendooram demonstrates hypoglycemic activity and that further clinical studies are required. The concurrent implementation of a strict dietary regimen reduces the ability to draw any meaningful conclusions from this report.

Kumar and Kumar (1995) studied the effects of the herbal preparation M-93 on 30 NIDDM (type 2) patients. Seventy-three percent of the patient population was between the ages of 41 and 60, and 34 percent were female. No information was given on selection criteria other than the fact that patients with FBS > 300, chronic renal failure, diabetic neuropathy, or diabetic ketoacidosis were excluded from this study.

M-93 consists of Bilva (Aegle marmelos); Nimba, also known as neem (Azadirachta indica); Tulsi (Ocimum sanctum); and Kalimircha (Piper nigrum). M-93 was given orally at a dose of 1 g three times a day for 1 month.

After 1 month of treatment with M-93, the mean FBS dropped 31.84 mg/dl, from 160.2 mg/dl to 128.36 mg/dl (p values were not reported), while the mean PPBS dropped 56.9 mg/dl, from 229.5 mg/dl to 172.6 mg/dl (p values not reported). No adverse effects were reported from this study.

The authors concluded that all patients treated with M-93 showed a positive response after 1 month of therapy.

Nanda, Chopra, Sahu, et al. (1998) studied the effects of an Ayurvedic herbal combination, Nishamalaki, on blood sugar and symptoms of an arm of type 2 diabetic patients. The patients (n=100, 20 percent female, ages 31–70 years) were recruited from the outpatient department of the Central Research Institute (Ayurveda) in Bhubaneshwar, India. The diagnosis of diabetes was made on the basis of an elevated fasting blood sugar and presence of symptoms. The socioeconomic status of the patients was not reported. Patients who were younger than 30 years and older than 70 years, and patients who had hypertension or diabetic renal and cardiac complications were excluded.

Details of the preparation of Nishamalaki or its ingredients were not reported in the study. The herbal combination was given at a dose of 1 g of powder with water twice daily for 6 weeks. All patients also received diet and lifestyle modification advice.

The results (see Appendix Table 23) were reported as follows. There was significant symptomatic improvement with the drug. Polyuria was present in 92 percent of patients before the study and decreased to 20 percent after the study. Similarly, turbid urine incidence decreased from 78 percent to 20 percent, excessive hunger decreased from 57 percent to 22 percent, and polydipsia decreased from 59 percent to 25 percent. There was no significant change in the incidence of obesity.

Appendix Table 23. Study results of Nanda, Chopra, Sahu, et al., 1998

Range of reduction of fasting blood sugar (mg/dl) | Percentage of patients in range | Response to treatment | Percentage of patients with response
0–30 | 45 | Good | 45
31–60 | 40 | Fair | 38
61–90 | 10 | Poor | 15
91 and greater | 5 | No | 2

Based on these results, the authors concluded that Nishamalaki is effective in lowering fasting blood sugar levels as well as reducing symptoms in diabetic patients.

Jain and Chakraborty (1987) studied the effects of an Ayurvedic herbal product called Nosulin on 20 NIDDM (type 2) patients (35 percent female, ages 35 to 70 years). The patients were classified into two arms: Arm I had 15 patients who were not taking any other medicine; Arm II had 5 patients who were concurrently taking 10 mg/day of the oral hypoglycemic agent glibenclamide. All patients were given 5 g of Nosulin twice daily, after lunch and dinner, and were also placed on an 1,800-calorie ADA diet. There was no blinding of either the patients or the researchers.

Each 5 g of Nosulin contains 4.5 g of Cyamopsis tetragonoloba (guar gum), 0.2 g of Cephalandra indica (tundika), 0.2 mg of Gymnema sylvestre (meshasringi), and a sufficient amount of excipients.

The authors reported a reduction of 25 to 30 percent in the mean blood sugar level for Arm I patients and a 50-percent reduction for Arm II patients. The actual numerical values and statistical significance of these results were not reported. The authors also reported a marked reduction in symptoms in all cases, as well as a decrease in the frequency and quantity of urine and a general sense of well being. No adverse effects were observed.

The researchers concluded that Nosulin appears to be a suitable therapeutic adjunct to oral hypoglycemic agents and dietary restrictions for diabetes. They also noted that further studies of Nosulin are currently underway. This preliminary study does not report any statistically significant results, and thus no conclusions can be inferred regarding Nosulin in the management of NIDDM (type 2) patients.

Sadhukhan, Roychowdhury, Banerjee, et al. (1994) reported on the hypoglycemic effects of an herbal anti-diabetic compound in a series of three studies. The patients (n=67) were recruited from the outpatient departments of the SSKM Hospital, Calcutta, India.

In the first study, 25 patients with type 1 or type 2 diabetes (ages 10–60 years, 32 percent female) were recruited. The socioeconomic characteristics and the inclusion/exclusion criteria were not reported. Patients who were taking oral hypoglycemic agents were asked to discontinue their medications 2 days prior to the study. Standard diet was prescribed to all the patients. The intervention consisted of an herbal preparation that contained guar gum (Cyamopsis tetragonoloba), 4 g; Trigonella foenum-graecum, 0.6 g; Cephalandra indica, 0.1 g; and Gymnema sylvestre, 0.2 g. The test drug was given for 2 days. An oral glucose tolerance test was done prior to starting therapy and after completion of therapy.

Results were reported for 11 out of the 25 patients as follows. The FBS improved from 221.18 mg/dl to 211.8 mg/dl. The 1-hour PPBS improved from 401.63 mg/dl to 316.0 mg/dl, and the 2-hour PPBS improved from 427.81 mg/dl to 341.45 mg/dl. The results for the remaining 14 patients were not reported and were said to be insignificant.

In the second of the three studies, 42 type 2 diabetic patients (29 percent female) were recruited. The socioeconomic characteristics and inclusion/exclusion criteria were not reported. Patients who were taking oral hypoglycemic agents were asked to discontinue their medications 2 days prior to the study. Standard diet was prescribed to all the patients. There were three consecutive intervention periods (arms). Arm I consisted of an herbal preparation that contained Cyamopsis tetragonoloba, 4 g; Trigonella foenum-graecum, 0.6 g; Cephalandra indica, 0.1 g; and Gymnema sylvestra, 0.2 g. This was taken twice a day for 2 days and was followed by 2 drug-free days. In Arm II, patients received 5 g of Cyamopsis tetragonoloba twice daily for 2 days, and this was followed by another 2-day drug-free period. In Arm III, patients received 5 g of Trigonella foenum graecum twice daily for 2 days. Fasting and post-prandial blood sugars were measured after each intervention period. Study results are shown in Appendix Table 24.

Appendix Table 24. Study results (second study) for Sadhukhan, Roychowdhury, Banerjee, et al., 1994

| Pre-study | Arm I | Arm II | Arm III
Mean fasting blood sugar (mg/dl) | 162.8 | 157.95 | 155.61 | 158.09
Mean 1-hour post-prandial blood sugar (mg/dl) | 236.05 | 219.19 | 178.00 | 219.14
Mean 2-hour post prandial blood sugar (mg/dl) | 235.64 | 215.52 | 119.62 | 212.67

The authors concluded that the blood-sugar lowering effects of the combination test drug, as well as the two separate herbs, were significant. The possibility of overlapping hypoglycemic effect from the previous drugs is a major limitation of this study.

In the third study, 12 non-diabetic patients (33.3 percent female) were recruited. The socioeconomic characteristics and inclusion/exclusion criteria were not reported. These non-diabetic patients were divided into three arms and received the same diet and drug interventions used for the diabetic patients in the second study. Fasting and post-prandial blood sugars were measured after each intervention period. Study results are shown in Appendix Table 25.

Appendix Table 25. Study results (third study) for Sadhukhan, Roychowdhury, Banerjee, et al., 1994

| Pre-study | Arm I | Arm II | Arm III
Mean fasting blood sugar (mg/dl) | 84.83 | 87.08 | 85.67 | 86.42
Mean 1-hour post-prandial blood sugar (mg/dl) | 125.42 | 118.58 | 108.83 | 115.50
Mean 2-hour post prandial blood sugar (mg/dl) | 113.42 | 105.75 | 95.83 | 99.33

The authors concluded that the combination test drug did not produce a significant decrease in blood sugar but that the individual herbs—Cyamopsis tetragonoloba and Trigonella foenum graecum—did produce a significant reduction in the fasting and post-prandial blood sugars. The possibility of overlapping hypoglycemic effects across arms is a limitation of these studies.

## Diet Studies

Acharya, Upadhyay, and Dwivedi (1996) reported the results of a study of a particular diet for diabetic patients (n=30, percent female and ages not given). Two type 1 diabetic patients and 28 type 2 diabetic patients were included. Twenty-five of the patients were newly diagnosed, and five patients were known to be diabetic. Inclusion/exclusion criteria and socioeconomic status were not reported. The diagnosis of diabetes was made on the basis of fasting and post-prandial blood sugar levels. The patients were classified into three categories, depending on their dosha body type: kaphaja (n=15), pittaja (n=10), and vataja (n=5).

The intervention consisted of a diet taken from Ayurvedic textbooks and prescribed according to the patient's body-type constitution. The diet included various cereals, pulses, vegetables, spices, and meats. The diet was prescribed for a total of 15 days. Most of the patients were hospitalized for the study. Study results are presented in Appendix Table 26.

Study results for Acharya, Upadhyay, and Dwivedi, 1996

| Before treatment | At 7 days | At 15 days
Fasting blood sugar (mg/dl) | 133 | 125.4 (p<0.001) | 123.5 (p<0.001)
Post-prandial blood sugar (mg/dl) | 236.3 | 231.6 (p<0.001) | 228.6 (p<0.001)

The most significant decrease in FBS and PPBS was reported in the kaphaja arm followed by the pittaja arm and, last, the vataja arm. The researchers also noted that the patients with newly diagnosed diabetes had a significant decrease in their blood sugars, but the patients with previously known diabetes, including type 1 diabetic patients, did not. A statistically significant improvement in the symptoms of polyuria, polydipsia, polyphagia, and weakness was reported. No significant improvement in cramping, decreased libido, and joint pains was noted.

The authors concluded that dietary management is highly effective in newly diagnosed diabetic patients and in kapha-predominant patients. They added that diet has a supportive role in the treatment of vata-predominant patients and in chronic cases of diabetes.

Pandya, Nirmal, and Mistry (1990) conducted a case series on the role of Pathya Ahara, a particular Ayurvedic diet, in the treatment of diabetes. The diet is characterized as being low in madhura rasa (sweet taste) items and high in complex carbohydrates such as kidney beans, barley, and wheat. The caloric value was approximately 1,500 to 2,000 calories per day. Sixteen patients were recruited from an Ayurvedic practice; but their demographics, including age and gender, and inclusion/exclusion criteria were not given. The diagnosis of diabetes was based on blood glucose level. The patients were classified into two arms. Of the 16 patients initially enrolled, 6 dropped out because of noncompliance with the diet.

During the 15-day study, Arm I received Pathyhara as the sole treatment. Arm II received the diet plus an Ayurvedic preparation consisting of Banga bhasma and Tulsirasa (holy basil or Ocinum sanctum). Based on a glucose tolerance test, the fasting blood sugar in Arm I was 169.3 mg/dl before treatment and 138.52 mg/dl after treatment (SD = 39.42, p <0.05). In Arm II, fasting blood sugar decreased from 238.25 mg/dl to 222.40 mg/dl, and the 2-hour post-prandial blood sugar decreased from 368.93 mg/dl to 317.43 mg/dl. All other urinary and blood glucose measures for both arms did not reach statistical significance.

The high percentage of dropouts was not included in the analysis (i.e., an intention to treat analysis was not done), and this could distort the positive results noted.

Kedar and Chakrabarti (1981), in an RCT, studied the effects of “gurmar,”^7^ beeja wood (Pterocarpus marsupium) water, and tamarind seeds (Tamarindus indica) on 30 NIDDM (type 2) patients (percent female not reported, ages 40 to 65 years). (Because there is no comparison arm not receiving an Ayurvedic intervention, this study is not reported in evidence table 1. The patients had previously been taking various diabetic treatments including gurmar, beeja wood water, or tamarind seeds. They were instructed to stop all anti-diabetic treatments for 8 days and to begin a low-carbohydrate, low-fat diet. There was no blinding of either the patients or the researchers.

Gurmar is Gymnema sylvestre, but here the term is applied to an herbal combination that also includes Aegele marmelos, Azadirachta indica (also known as Melia azadirachta), and Eugenia jambolana.

The patients were divided into three treatment arms: Arm I patients (n =10) were given 50 ml of a gurmar aqueous extract preparation twice a day, after lunch and dinner, for 7 days. This preparation consisted of 100 g of gurmar (Gymnema sylvestre), 100 leaves of bael (Aegle marmelos), 200 g of leaves of Melia azadiracta 8, and 25 g of javaplum (Eugenia jambolana) seed powder. Arm II patients (n=10) received 200 ml of beeja wood water twice a day, after lunch and dinner, for 1 month. This liquid was prepared by holding the water for 12 hours in pots made of beeja wood. Arm III patients (n =10) received 10 tamarind seeds daily for 1 month. The seeds were first soaked in water and then eaten the next day after lunch. The study results are reported in Appendix Table 27.

Also known as Azadirachta indica.

Appendix Table 27. Study results of Kedar and Chakrabarti

Treatment | Initial PPBS (mg/ dl) | 1-week PPBS (mg/dl) | 4-week PPBS (mg/dl) | Pre-treatment cholesterol (mg/dl) | Post-treatment cholesterol (mg/dl) | Pre-treatment triglycerides (mg/dl) | Post-treatment triglycerides (mg/dl)
Arm I(Gurmar prep. | 235.5 | 135.26 (p<0.01) | 242.16 | 210.4 | 193.4 | 139.1 | 90.6 (p<0.01)
Arm II(Beeja wood water) | 271.5 | 168.2 (p<0.01) | 156.52 (p<0.01) | 234.5 | 219.0 | 192.2 | 83.4 (p<0.01)
Arm III(Tamarind seed) | 295.0 | 182.8 (p<0.05) | 162.0 (p<0.01) | 248.9 | 179.2 (p<0.01) | 197.8 | 93.4 (p<0.01)

PPBS = 2-hour post-prandial blood sugar

The three treatments described in this study appear to have some promise in the reduction of post-prandial blood glucose and lipid levels. The small number of patients and the number of different substances studied within a single study as well as the lack of a placebo comparison arm make it difficult to draw meaningful conclusions. However, this study does indicate that the gurmar preparation, beeja wood water, and tamarind seed merit further investigation. The Jadad score for this study is 1.

Characteristics of Studies Not Included in Further Analysis

First author
Year | | | | | Intervention group
Title | | Diagnosis | | | Intervention
Location | | Diagnostic criteria | | | Plant parts used
Study design | | Gender | | Time at followup | # Entering study
Jadad | | Age | | | # Completing study | | Outcomes
Marvah | | Diagnosis: | Type 2 diabetes | 6 month or less | Arm 1: Cassia auriculata , diet | | Outcomes: Clinical symptoms, GTT, FBS, lipid panel, urine glucose, and blood urea
1900 | | Diagnostic criteria: Ayurvedic, FBS
A clinical study on the role of an indigenous drug | | | | | Plant part: | N/A
Avartaki (Cassia auriculata | | % Female: | Not reported | | Preparation: | N/A | Symptomatic relief was reported in 100% in Avarataki group. The effect on GTT revealed a significant reduction (25.97% p<0.05) in the 2^nd^ hour. Serum cholesterol reduced by 8.42% p<0.05. Blood urea reduced by 12.67% p<0.01.
| | % under 18: | Not reported | | N entering: | Not reported
Location of treatment: | India Sub-continent | % over 65 | Not reported | | N completing | 8
Study design | Case series
Sivaprakasam | | Diagnosis: | Type 2 diabetes: | Before and after 6 months | Arm 1: Cassia auriculata , oral hypoglycemic, UCC | | Outcomes: FBS
1985 | | Diagnostic criteria: | GTT
Clinical evaluation of the effect of Siddha drugs on diabetes mellitus | | % Female | 28 | | Plant part: | Leaf | The formulations of Avarai samoola chooranam in dosages of 1gm TID failed to show any significant reduction in blood glucose levels.
| | % under 18: | 0 | | Preparation: | dry powdered
Location of treatment | India Sub-continent | % over 65: | Not reported | | N entering: | Not reported
Study design: | Case series | | | | N completing: | 25
Sivaprakasam | | Diagnosis: | Type 2 diabetes | More than 6 months | Arm 1: Psidium guajava (Avarai), diet | | Outcome: FBS
1985 | | Diagnostic criteria: | UBS and GTT
Clinical evaluation of the effect of Siddha drugs on diabetes mellitus | | % Female | | | Plant part: | Leaf | The formulations of Koiyya chooranam in dosages of 1gm TID failed to show any significant reduction in blood glucose levels.
| | % under 18: | 0 | | N entering: | Not reported
Location of treatment: | India Sub-continent | % over 65 | Not reported | | N completing | 20
Study design: | Case series
Chandola | | Diagnosis: | Type 2 diabetes: | 6 months or less | Arm 1: C. tamala , diet | | Outcomes: FBS, insulin levels
1980b | | Diagnostic criteria: | FBS and GTT
Effect of C. tamala on plasma insulin vis-à-vis blood sugar in patients of diabetes mellitus | | | | | Plant part: | Leaf | The 15 day study showed a statistically significant reduction in mean fasting blood sugar of 56.6 mg/dl (p<0.05) and a non-significant increase in plasma insulin levels of 9.74 μu/ml (p>0.05).
| | % Female | 20 | | Preparation: | powdered dried leaf
| | % under 18 | 0 | | N entering: | Not reported
Location of treatment: | India Sub-continent | % over 65: | 40 | | N completing: | 5
Study design | Case series
Chandola | | Diagnosis: | Type 2 diabetes: | 6 months or less | Arm 1:C. tamala | | Outcomes: FBS, insulin levels
1980b | | Diagnostic criteria: | FBS and GTT
Effec of C. tamala on plasma insulin vis-à-vis blood sugar in patients of diabetes mellitus | | | | | Plant part: | Leaf | The 2-hour study also showed a significant reduction in mean fasting blood sugar of 56.5 mg/dl (p<0.05) and a significant increase in serum insulin levels of 23 μu/ml (p<0.05).
| | % Female: | 0 | | Preparation: | powdered dried leaf
| | % under 18: | 0 | | N entering: | Not reported
Location of treatment: | India Sub-continent | % over 65: | 25 | | N completing: | 4
Study design | Case series
Chandola* | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm: C. tamala | | Outcomes: FBS
1980a | | Diagnostic criteria: | FBS and GTT
Hypoglycaemic response of C. tamala in patients of maturity onset (insulin independent) diabetes | | | | | Plant part: | Leaf | Mean blood sugar decreased from 166.28 mg/dl ar 1 hour (p<0.02) and 122.28 mg/dl at 2 hours (p<0.01).
| | % Female: | 0 | | Preparation: | Powedered dried
| | % under 18: | 0 | | N entering: | N/A
Location of treatment: | India Sub-continent | % over 65: | 14 | | N completing: | 7
Study design | Case series
Chaturvedi | | Diagnosis: | Type 2 diabetes | 6 months or less | Series 1: Diet | | Series 1 outcomes: Clinical symptoms, urine glucose, blood glucose
1983 | | Diagnostic criteria: | FBS and GTT
Experimental and clinical studies on diabetic mellitus evaluating the efficacy of an indigenous oral hypoglycaemic drug Arani (Clerodendron phlomidis) | | | | | Plant part: | Leaf | N/A
| | % Female: | Not reported | | Preparation: | Tea/decoction | See Series 2.
| | % under 18: | Not reported | | N entering: | Not reported
| | % over 65: | Not reported | | N completing: | 4
| | | | | Series 2:Clerodendron phlomides, diet | | Series 2 outcomes: Clinical symptoms, urine glucose, blood glucose
Location of treatment: | India Sub-continent | | | | Plant part: | N/A
Study design | Case series | | | | Preparation: | N/A | A improvement in symptoms was observed in Arani teated diabetic group: urine became free of sugar in 46% of patients (no p value given). Also a marked reduction in blood sugar values lowered down ot 149mg/dl from 202mg/dl.
| | | | | N entering: | Not reported
| | | | | N completing: | 13
| | | | | Series 3: Oral hypoglycemic, diet | | Series 3 outcomes: Clinical symptoms, urine glucose, blood glucose
| | | | | Plant part: | Fruit
| | | | | Preparation | Taken whole, | See Series 2.
| | | | | | powdered of dried fruit
| | | | | N entering: | Not reported
| | | | | N completing: | 3
| | | | | Series 4: Insulin, diet | | Series 4 outcomes: Clinical symptoms, urine glucose, blood glucose
| | | | | Plant part: | Fruit
| | | | | Preparation: | Tea/decoction | See Series 2.
| | | | | N entering: | Not reported
| | | | | N completing: | 3
Nande | | Diagnosis: | Normal and | 6 months or less | Arm 1: Eugenia jambolana | | Arm 1 outcomes: FBS, mean 3-hour blood glucose
1983 | | | type 2 diabetes
Effect of Jambu fruit pulp (Eugenia jambolanaLam) on blood sugar levels in healthy volunteers and diabetes | | Diagnostic criteria: | FBS | | Plant part: | Fruit
| | | | | Preparation: | pulp | Mean blood sugar decreased from 75.3 +/- 2.63 mg/dl to 68.3 +/-2.11 mg/dl at 3 hours (p<0.05).
| | % Female: | 25 | | N entering: | 7
| | % under 18: | 0 | | N completing: | 7
Location of treatment: | India Sub-continent | % over 65: | Not reported | | Arm 2: Eugenia jambolana | | Arm 2 outcomes: FBS, mean 3-hour blood glucose
Study design | Cohort
| | | | | Plant part: | Fruit
| | | | | Preparation: | pulp | Mean blood sugar decreased from 240 +/- 44.3 mg/dl to 272 +/-49.67 mg/dl at 3 hours (p<0.05).
| | | | | N entering: | 5
| | | | | N completing: | 5
Sepaha | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Pterocarpus marsupium | | Arm 1 outcomes: serum glucose levels.
1956 | | Diagnostic criteria | FBS
Clinical observation on the antidiabetic properties of Pterocarpus marsupium and Eugenia Jambolana | | | | | Plant part: | N/A | There ws a nonsignificant reduction in serum glucose level in 7% of the Peterocarpus patients.
| | % Female: | 9.5 | | Preparation | N/A, water/alc extract
| | % under 18 | 0 | | N entering | 17
Location of treatment: | India Sub-continent | % over 65 | 0 | | N completing | 14
Study design: | Case series | | | | Arm 2: Eugenia jambolana | | Arm 2 outcomes: serum glucose levels.
| | | | | Plant part | Seed | There was a nonsignificant reduction in serum glucose levels in 42% of the Eugenia patients
| | | | | Preparation | N/A, powdered
| | | | | N entering | 7
| | | | | N completing | 5
Raghuram | | Diagnosis | Type 2 diabetes | 6 months or less | Arm 1: Diet | | Arm 1 outcomes: FBS, PPBS, glucose area under the curve
1994 | | Diagnostic criteria | GTT
Effect of fenugreek seeds on intravenous glucose disposition in non-insulin dependent diabetic patients | | | | | Plant part | N/A
| | % Female | Not reported | | Preparation | N/A | The study showed a statistically significant reduction in blood glucose levels at 40, 50 and 60 minutes after a glucose load (p<0.02). (the actual values are not reported). Additionally, the study also demonstrated a significant decrease in serum glucose area under the curve (p<0.05), glucose half-life (p<0.02), as well as significant increases in serum glucose metabolic clearance rate (p<0.02) and glucose erythrocyte insulin receptors (p<0.02).
| | % under 18 | 0 | | N entering | 10
| | % over 65 | 0 | | N completing | 10
Location of treatment: | India Sub-continent
Study design: | RCT
Total Jadad score | 1
Randomized | Yes
Randomization appropriate | Not described
Double-blind | Not described
Blinding appropriate | Not described
Withdrawals/dropouts described | No
| | | | | Arm 2: Fenugreek, diet | | See Arm 1.
| | | | | Plant part | Seed
| | | | | Preparation | Powdered seed in bread
| | | | | N entering | 10
| | | | | N completing | 10
Sharma | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, diet | | Outcomes: FBS, PPBS, insulin levels, cholesterol, HDL, VLDL, and LDL
1990 | | Diagnostic criteria: | GTT
Hypoglycaemic effect of fenugreek seeds in non-insulin dependent diabetic subjects. | | % Female: | 33 | | Plant part: | Seed
| | % under 18: | 0 | | Preparation: | N/A, seed powder extract | This cross-over study showed a statistically significant reduction in mean fasting blood sugar of 42 mg/dl (p<0.05). There was also a significant reduction in the serum insulin levels of 17.6 μU/l (p<0.05) and in 2-hour post-prandial blood glucose of 110 mg/dl (p<0.01). There was also a significant reduction in total serum cholesterol of 29 mg/dl (p<0.001) and in LDL and VLDL cholesterol of 23 mg/dl (p<0.001).
| | % over 65: | 0 | | N entering: | 15
Location of treatment: | India Sub-continent | | | | N completing: | 15
Study design: | RCT
Total Jadad score | 2 | | | | Arm 2: Diet
Randomized | Yes
Randomization appropriate | Not described | | | | Plant part: | N/A
Double-blind | Not described | | | | Preparation: | N/A
Blinding appropriate | Not described | | | | N entering: | 15
Withdrawals/dropouts described | Yes | | | | N completing: | 15
Sharma | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, diet | | Outcomes: FBS, PPBS, insulin levels, cholesterol, HDL, VLDL, and LDL
1990 | | Diagnostic criteria: | GTT
Hypoglycaemic effect of fenugreek seeds in non-insulin dependent diabetic subjects. | | % Female: | Not reported | | Plant part: | Seed
| | % under 18: | 0 | | Preparation: | N/A, seed powder extract | There was a significant decrease in mean fasting blood glucose of 41 mg/dl (p<0.05) as well as significant reductions in 24-hour urinary glucose excretion, serum cholesterol, and triglyceride levels (p<0.05). No adverse effects were reported in either experimental group.
| | % over 65: | 0 | | N entering: | 5
Location of treatment: | India Sub-continent | | | | N completing: | 5
Study design: | RCT
| | | | | Arm 2: Diet
Total Jadad score | 2
Randomized | Yes | | | | Plant part: | N/A
Randomization appropriate | Not described | | | | Preparation: | N/A
Double-blind | Not described | | | | N entering: | 5
Blinding appropriate | Not described | | | | N completing: | 5
Withdrawals/dropouts described | Yes
Sharma | | Diagnosis | Type 1 diabetes | 6 months or less | Arm 1: UCC, insulin | | Arm 1 outcomes: FBS, PPBS, insulin levels, cholesterol, LDL, VLDL, HDL
1990 | | Diagnostic criteria | FBS and GTT
Effect of fenugreek seeds on blood glucose and serum lipids in type I diabetes | | | | | Plant part | N/A
| | % Female | 33 | | Preparation | N/A, none | This cross-over study showed a statistically significant reduction in mean FBS of 84 mg/dl (p<0.01) and in the 1½-hour PPBS of 94 mg/dl (p<0.055) in the experimental group. There was no significant reduction in the serum insulin levels and there was a significant reduction in total serum cholesterol (p<0.001) and in LDL and VLDL cholesterol (p<0.01).
| | % under 18 | 40 | | N entering | 10
Location of treatment: | India Sub-continent | % over 65 | 0 | | N completing | 10
Study design: | RCT
Total Jadad score | 1
Randomized | Yes
Randomization appropriate | Not described
Double-blind | Not described
Blinding appropriate | Not described | | | | Arm 2: Fenugreek | | See Arm I.
Withdrawals/dropouts described | No | | | | Plant part | Seed
| | | | | Preparation | N/A, defatted seed powder
| | | | | N entering | 10
| | | | | N completing | 10
Sharma | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, diet | | Outcomes: Cholesterol, LDL, VLDL, and triglycerides, HDL
1996b | | Diagnostic criteria | FBS, GTT
Hypolipidaemic effect of fenugreek seeds:a chronic study of non-insulin dependent diabetic patients | | | | | Plant part: | Seed
| | % Female: | 25 | | Preparation: | soup w/powder, water | Significant reductions in total cholesterol, LDL, VLDL, and triglyceride levels in patients who used fenugreek in addition to an isocaloric diet. Specifically, mean serum cholesterol level in the diabetic patients was 241+/- 6.2 mg/dl, which reduced to 199+/- 6.7 mg/dl (p<0.001) after 24 weeks of treatment. LDL cholesterol had a 16% reduction, triglyceride levels decreased 15% after 24 weeks of treatment.
| | % under 18: | 0 | | N entering: | 60
| | % over 65: | Not reported | | N completing: | 60
Location of treatment: | India Sub-continent
Study design: | Case series
Sharma | | Diagnosis: Normal and type 2 diabetes | | 6 months or less | Series 1: Fenugreek | | Outcomes: Blood glucose, PPBS, serum insulin
1986 | | Diagnostic criteria: | GTT
Effect of fenugreek seeds and leaves on blood glucose and serum insulin responses in human subjects | | | | | Plant part: | Seed
| | % Female: | Not reported | | Preparation: | Taken whole | Results revealed that the gum isolate significantly reduced plasma glucose at 30 and 60 minutes (p<0.05). Gum significantly altered the serum insulin levels at 30 minutes (p<0.01) and at 60 minutes (p<0.05). The other preparations did show a consistent reduction in plasma glucose with serum insulin.
| | % under 18: | Not reported | | N entering: | 8
| | % over 65: | Not reported | | N completing: | 8
Location of treatment: | India Sub-continent
Study design: | Case series
| | | | | Series 2: Fenugreek | | See Series 1.
| | | | | Plant part: | Seed
| | | | | Preparation: | powdered
| | | | | N entering: | 6
| | | | | N completing: | 6
| | | | | Series 3: Fenugreek | | See Series 1.
| | | | | Plant part: | Seed
| | | | | Preparation: | Gum isolate
| | | | | N entering: | 6
| | | | | N completing: | 6
| | | | | Series 4: Fenugreek | | See Series 1.
| | | | | Plant part: | Seed
| | | | | Preparation: | Degummed seeds
| | | | | N entering: | 8
| | | | | N completing: | 8
| | | | | Series 5: Fenugreek | | See Series 1.
| | | | | Plant part: | Seed
| | | | | Preparation: | Cooked seeds
| | | | | N entering: | 8
| | | | | N completing: | 8
| | | | | Series 6: Fenugreek | | See Series 1.
| | | | | Plant part: | Leaf
| | | | | Preparation: | Cooked leaves
| | | | | N entering: | 4
| | | | | N completing: | 4
Sharma | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, diet | | Outcomes: Fasting blood glucose, PPBS, cholesterol, insulin levels
1986 | | Diagnostic criteria: | GTT
Effect of fenugreek seeds and leaves on blood glucose and serum insulin responses in human subjects | | | | | Plant part: | Seed
| | % Female: | Not reported | | Preparation: | xtracted/defatted meal | Fasting blood glucose pre-treatment 128.8+/- 18.9 reduced to 102.8+/- 18.9 (p<0.05) after treatment. 2-hour PPBS pre-treatment 247.6+/- 54.7 reduced to 191.6+/- 35.2 (p<0.05) after treatment. Cholesterol improved from 231 to 204 mg/dl (p<0.05).
| | % under 18: | Not reported | | N entering: | 5
| | % over 65: | Not reported | | N completing: | 5
Location of treatment: | India Sub-continent
Study design: | Case series
Smith | | Diagnosis: | Normal patients | 6 months or less | Arm 1: Guar gum, diet | | Results were not reported for Arm 1.
1982 | | Diagnostic criteria: | FBS
Effect of a modified guar gum preparation on glucose and lipid levels in diabetics and healthy volunteers | | | | | Plant part: | Gum
| | % Female: | 67% | | Preparation: | powder
| | % under 18: | 0 | | N entering: | 6
| | % over 65: | Not reported | | N completing: | 6
Location of treatment: | Scandinavia
Study design: | Case series
| | Diagnosis: Type 1 and type 2 diabetes | | | Arm 2: Guar gum, diet, oral hypoglycemi, insulin | | Arm 2 Outcomes: Cholesterol, triglycerides, alpha-lipoprotein
| | Diagnostic criteria: | FBS
| | % Female: | Not reported | | Plant part: | Gum | Cholesterol was reduced by 14% in diabetics after 3 weeks treatment with guar gum. Alpha-lipoprotein was not changed. Neither triglycerides nor body weights changes during treatment. Guar gum represents an interesting and possibly beneficial fiber supplement.
| | % under 18: | 0 | | Preparation | powder
| | % over 65: | Not reported | | N entering: | 17
| | | | | N completing: | 17
Balasubramaniam | | Diagnosis | Type 2 diabetes | 6 month or less | Arm 1: Gymnema sylvestre | | Outcomes: FBS, PPBS, body weight
1988 | | Diagnostic criteria | GTT
Hypoglycaemic effect of Gymnema sylvestre on diabetic patients | | | | | Plant part | Leaf | The study showed a statistically significant reduction in fasting blood glucose of 50.5 mg/dl and 2-hour blood glucose levels of 74.2 mg/dl at 21 days (p<0.05) as compared with the same patients prior to treatment with Gymnema. The study also found a non-significant increase in body weight of 0.9 kg during this same 21-day period.
| | % Female | Not reported | | Preparation | N/A, powdered
| | % under 18 | Not reported | | N entering | 8
Location of treatment: | India Sub-continent | % over 65 | Not reported | | N completing | 8
Study design: | Case series
Kothe | | Diagnosis: | Not described | 6 months or less | Arm 1: Gymnema sylvestre, diet | | Homeopathic study
1997 | | Diagnostic criteria: | FBS and PPBS | | | | Outcomes: FBS
Antidiabetic effects of Gymnema sylvestre in NIDDM - a short study | | | | | Plant part: | Leaf
| | % Female: | 33 | | Preparation: | aq. ext. mother tincture | 7 cases severe diabetics: 3 excellent response; 2 moderate response; 2 no response. 14 cases non-severe diabetics: 9 good response; 2 moderate response; 3 no response.
| | % under 18: | 0 | | N entering: | 21
Location of treatment: | India Sub-continent | % over 65: | Not reported | | N completing: | 21
Study design: | Case series
Balasubramaniam | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Gymnema sylvestre | | Arm 1 outcomes: FBS, PPBS, triglycerides, cholesterol
1992 | | Diagnostic criteria: | FBS, GTT, and Hg A_1c_
Studies on the effect of Gymnema sylvestre on diabetics | | | | | Plant part: | Leaf
| | | | | Preparation: | leaf powder | In the group of normal patients, there was no significant change from day 7 to day 14 in any of the parameters.
| | % Female: | Not reported | | N entering: | 16
Location of treatment: | India Sub-continent | % under 18: | 0 | | N completing: | 16
Study design: | CCT | % over 65: | Not reported
Total Jadad score: | 0
Randomized: | No
Randomization appropriate: | No
Double-blind: | No
Blinding appropriate: | No
Withdrawals/dropouts described: | No | | | | Arm 2: Gymnema sylvestre | | Arm 2 outcomes: FBS, PPBS, triglycerides, cholesterol
| | | | | Plant part: | Leaf
| | | | | Preparation: | leaf powder | There was a statistically significant reduction in their FBS level from 151.7 mg/dl to 101.2 mg/dl at 21 days, and a reduction in post-prandial blood sugar from 215.7 mg/dl to 141.5 mg/dl at 21 days.
| | | | | N entering: | 7
| | | | | N completing: | 7
| | | | | Arm 3: Gymnema sylvestre, oral hypoglycemic | | Arm 3 outcomes: FBS, PPBS, triglycerides, cholesterol
| | | | | Plant part: | Leaf | There was a decrease in FBS from 157.8 mg/dl to 136.3 mg/dl at 7 days and the FBS continued to be low on the 14^th^ day at 133.1. The PPBS decreased from 244.8 mg/dl to 144.7 mg/dl at day 7 and 135.5 mg/dl at day 14.
| | | | | Preparation: | leaf powder
| | | | | N entering: | 36
| | | | | N completing: | 36
Khare | | Diagnosis: Normal and | type 2 diabetes | 6 months or less | Arm 1: Gymnema sylvestre | | Arm 1 outcomes: FBS, PPBS
1983 | | Diagnosis criteria: | FBS, GTT, and Hg A_1c_
Hypoglycaemic activity of an indigenous drug (Gymnema sylvestre, ‘Gurmar’) in normal and diabetic persons [letter] | | | | | Plant part: | Leaf | FBS decreased from 80.2 to 69.2 mg/dl (p<0.05) and PPBS decreased from 76.7 mg/dl to 66.8 mg/dl (NS).
| | | | | Preparation: | Tea/decoction
| | % Female: | 38 | | N entering: | Not reported
| | % under 18 | 0 | | N completing: | 10
Location of treatment: | India Sub-continent | % over 65: | 0
Study design: | Cohort | | | | Arm 2: Gymnema sylvestre | | Arm 2 outcomes: FBS, PPBS
| | | | | Plant part: | Leaf | FBS decreased from 135.7 to 110.7 mg/dl (p<0.02) and PPBS decreased from 152.7 mg/dl to 121.1 mg/dl p<0.01
| | | | | Preparation: | Tea/decoction
| | | | | N entering: | Not reported
| | | | | N completing: | 6
Akhtar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Mormodica charantia | | outcomes: FBS, PPBS
1982 | | Diagnostic criteria | GTT
Trial of Momordica charantia Linn. (Karela) powser in patients with maturity onset diabetes | | | | | Plant part | Fruit | There was a significant decrease in fasting glucose levels of 93 mg/dl (p<0.001) and post-prandial glucose levels at 2 hours of 130 mg/dl (p<0.001).
| | % Female | 50 | | Preparation: | deleted powder
| | % under 18 | 0 | | N entering: | 8
Location of Treatment: | India Sub-continent | % over 65 | 0 | | N completing: | 8
Study design: | Case series
Baldwa | | Diagnosis: | Normale, type 1, and type 2 diabetes | 6 months or less | Arm 1: Placebo | | Outcomes: FBS in all arms
1977
Clinical trial in patients with diabetes mellitus of an insulin-like compound obtained from plant source | | Diagnostic criteria: | GTT | | Plant part: | N/A | Arm 1: The vegetable insulin produced an insulin-like effect. Placebo injections in control groups did not produce any reduction in blood sugars.
| | | | | Preparation: | N/A
| | % Female: | 13 | | N entering: | 5
Location of treatment: | India Sub-continent | % under 18 | Not reported | | N completing: | 5
Study design: | CCT | % over 65: | 0
Total Jaded score: | 1
Randomized: | No
Randomization appropriate: | Not applicable | | | | Arm 2: Placebo | | See Arm 1.
Double-blind: | Not described
Blinding appropriate: | Not described | | | | Plant part: | N/A
Withdrawals/dropouts described: | Yes | | | | Preparation: | N/A
| | | | | N entering: | 5
| | | | | N completing: | 5
| | | | | Arm 3: Mormodica charantia | | See Arm 1.
| | | | | Plant part: | Fruit
| | | | | Preparation: | purif veg insuln ext
| | | | | N entering: | 9
| | | | | N completing: | 9
Leatherdale | | Diagnosis | Type 2 diabetes | 6 months or less | Arm 1: Mormodica charantia | | Outcomes: Area under glucose curve, Hg A_1c_ and insulin levels
1981 | | Diagnostic criteria | GTT
Improvement in glucose tolerance due to Momordica charantia (karela) | | | | | Plant part | Fruit
| | % Female | 33 | | Preparation | Taken whole, juice | The study showed a significant reduction in plasma glucose levels during the glucose tolerance test at 30 minutes (p<0.05), at 60 minutes (p<0.01), and at 90 minutes (p<0.001) compared with controls. Only areas under glucose curve and not the actual blood glucose levels were reported. The study also showed a statistically significant reduction in glycosylated hemoglobin of 1.7% (p<0.01) in the patients who used fried karela compared with the pre-study levels.
| | % under 18 | Not reported | | N entering | 9
Location of treatment: | Europe | % over 65 | Not reported | | N completing | 9
Study design: | Case series
Welihinda | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Momordica charantia | | Outcomes: FBS, PPBS, area under glucose tolerance curve
1986 | | Diagnostic criteria | GTT
Effect of Momordica charantia on the glucose tolerance in maturity onset diabetes | | | | | Plant part: | Fruit
| | % Female: | Not reported | | Preparation: | Deleted juice | The glucose tolerance curves of all 18 patients obtained after ingestion of M. charantia were compared to the corresponding curves after the administration of water. This analysis revealed that 13 patients showed a significant improvement in glucose tolerance and 5 patients showed no improvement. In the analysis of the total data, the mean total area under the test glucose tolerance curves (187.0 sq. cm) was significantly lower than the area under the curve (243.6 sq. cm) for the controls (p<0.001).
| | % under 18: | Not reported | | N entering: | 18
Location of treatment | India Sub-continent | % over 65: | Not reported | | N completing: | 18
Study design: | Case series
Srivastava | | Diagnosis: | Type 2 diabetes | 6 months or less | Series 1: Mormodica charantia, diet | | Series 1 outcomes: Clinical symptoms, Hg A_1c_, blood and urine glucose
1993 | | Diagnostic criteria: GTT and Hb A_1c_
Antidiabetic and adaptogenic properties of Momordica charantia extract, an experimental and clinic evaluation | | | | | Plant part: | Fruit
| | % Female: | 0 | | Preparation: | Taken whole, powder of dried fruit | There was a trend in lowered blood glucose levels, it was not statistically significant.
| | % udner 18: | 0
| | % over 65: | Not reported | | N entering: | Not reported
Location of treatment: | India Sub-continent | | | | N completing: | 5
Study design: | Case series
| | | | | Series 2: Mormodica charantia, diet | | Series 2 outcomes: Clinical symptoms, Hg A_1c_, blood and urine glucose
| | | | | Plant part: | Fruit
| | | | | Preparation: | Tea/decoction | Hg A_1c_ decreased from 8.37 to 6.95 p<0.01
| | | | | N entering: | Not reported
| | | | | N completing: | 7
Srividya | | Diagnosis: | Not described | 6 months or less | Arm 1: UCC | | Arm 1 outcomes: FBS
1995 | | Diagnostic criteria: | FBS
Diuretic, hypotensive and hypoglycaemic effect of Phyllanthus amarus. | | | | | Plant part: | N/A | No significant change in FBS
| | % Female: | 56 | | Preparation: | N/A
| | % under 18: | 0 | | N entering: | 5
Location of treatment | India Sub-continent | % over 65: | 0 | | N completing: | 5
Study design: | Cohort
| | | | | Arm 2: Phyllanthus amarus | | Arm 2 outcomes: FBS
| | | | | Plant part: | Whole plant | Mean fasting blood sugar in Arms 2 and 3 patients decreased from 126.4 to 109.4 (p<0.001).
| | | | | Preparation: | powdered whole plant
| | | | | N entering: | 5
| | | | | N completing: | 5
| | | | | Arm 3: Phyllanthus amarus | | See Arm 2.
| | | | | Plant part: | Whole plant
| | | | | Preparation: | powdered
| | | | | N entering: | 4
| | | | | N completing: | 4
Mathew | | Diagnosis | Not described | 6 months or less | Arm 1: Onion | | Outcomes: FBS, PPBS
1975 | | Diagnostic criteria | Not described
Hypoglycaemic effects of onion, Allium cepa Linn on diabetes mellitus - a preliminary report | | | | | Plant part: | N/A | According to the authors, there was a rise in blood sugar of 75–90 mg/dl without the onion, but only a rise of 25–50 mg/dl when onion was used. Moreover, when onion was used, the blood sugar values came down to normal, which was not the case when onion was not used. No adverse effects were reported from this trial.
| | % Female: | 33% | | Preparation: | N/A, ether extracted
| | % under 18 | Not reported | | N entering: | 3
Location of treatment: | India Sub-continent | % over 65 | Not reported | | N completing: | 3
Study design: | Case series
Sharma | | Diagnosis: | Normal | 6 months or less | Series 1: None | | It was observed that the effects of aqueous extract of raw onion prepared from 25 gm. and 50 gm of onion were the same as those of raw onion in the same doses. Further the authors reported that the onion extract when administered in various doses along with glucose during oral GTT reduced hyperglycemia in a dose-dependent manner. The study showed no effect of onion on fasting glucose levels. It was reported that the blood sugar lowering effect of various doses of onion extract was statistically significant (p<0.05 to <0.01)and comparable to the effect of tolbutamide.
1977 | | Diagnostic criteria: | Not described
Antihyperglycemic effect of onion effect on fasting blood sugar and induced hyperglycemia in man | | | | | Plant part: | N/A
| | % Female: | 10 | | Preparation: | N/A
| | % under 18 | 0 | | N entering: | 20
Location of treatment: | India Sub-continent | % over 65: | 0 | | N completing: | 20
Study design: | Case series
| | | | | Series 2: Onion | | See Series 1.
| | | | | Plant part | bulb
| | | | | Preparation | aqueous extract
| | | | | N entering | 5
| | | | | N completing | 5
| | | | | Series 3: Onion | | See Series 1.
| | | | | Plant part | bulb
| | | | | Preparation | aqueous extract
| | | | | N entering | 5
| | | | | N completing | 5
| | | | | Series 4: Onion | | See Series 1.
| | | | | Plant part | bulb
| | | | | Preparation | aqueous extract
| | | | | N entering | 5
| | | | | N completing | 5
| | | | | Series 5: Onion | | See Series 1.
| | | | | Plant part | bulb
| | | | | Preparation | boiled onion
| | | | | N entering | 5
| | | | | N completing | 5
| | | | | Series 6: Onion | | See Series 1.
| | | | | Plant part | bulb
| | | | | Preparation | aqueous extract
| | | | | N entering | 3
| | | | | N completing | 3
| | | | | Series 7: Oral hypoglycemic | | See Series 1.
| | | | | Plant part | N/A
| | | | | Preparation | N/A
| | | | | N entering | 5
| | | | | N completing | 5
| | | | | Series 8: Distilled water | | See Series 1.
| | | | | Plant part | N/A
| | | | | Preparation | N/A
| | | | | N entering | 5
| | | | | N completing | 5
Rajesekharan | | Diagnosis | Type 1 and | 6 months or less | Arm 1: Pterocarpus marsupium | | Outcomes: FBS, urine blood sugar, symptoms
1976 | | | type 2 diabetes
Vijaysar, Pterocarpus maruspium, in the treatment of madhumeda (diabetes mellitus) - a clinical trial | | Diagnostic criteria | FBS and UBS | | Plant part | Heartwood
| | | | | Preparation | powdered | There was a good to fair improvement in symptoms of polyphagia, polydipsia and polyuria in a majority of cases. Out of 23 patients for whom blood sugar was reported only 8 showed a good ti fair response.
| | % Female | 40 | | N entering | X
Location of treatment: | India Sub-continent | % under 18 | 0 | | N completing | 35
Study design: | Case series | % over 65 | Not reported
Shankar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Abraga Chendooram ( Abragam-black mica, Vengaram-borax, Trianthema decandra, Adhatoda zeylanica, Ficus benghalensis purified with Sesbania grandiflora, vinegar and Calotropis gigantea), diet | | This study did not provide information on the actual fasting blood sugar results. Instead, patients were categorized into “complete relief” (normal blood sugar levels), “partial relief” (blood sugar levels slightly above normal - no actual range given), and “no relief” (no change in blood sugar levels). At 45 days, 35 patients (59%) demonstrated complete relief, 20 (33%) demonstrated partial relief, and 5 (8%) showed no relief.
1988 | | Diagnostic criteria: | GTT
Clinical Studies of Abraga (Mica) chendooram in the Management of Diabetes Mellitus (Neerazhivu)
| | % Female: | 45
| | % under 18: | 0
Location of treatment: | India Sub-continent | % over 65 | 10
Study design: | Case series
| | | | | Plant part: | Leaf and root
| | | | | Preparation:Ayurvedic preparation, tea/decoction, powdered
| | | | | N entering: | Not reported
| | | | | N completing: | 60
Kumar | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: M-93: Aegle marmelos, Azadirachta indica, Ocimum sanctum, Piper nigrum | | Outcomes; FBS, PPBS
1995 | | Diagnostic criteria: | Ayurvedic, FBS
A clinical trial Of M-93 compound in the management of Madhumeha (diabetes mellitus) | | | UBS, and GTT | | | | The mean FBS dropped 31.84 mg/dl from 160.2 mg/dl to 128.36 mg/dl while the mean PPBS dropped 56.9 mg/dl from 229.5 mg/dl to 172.6 mg/dl after 1 month of treatment
| | | | | Plant part | Leaf and fruit
| | % Female: | 34 | | Preparation: | dried
Location of treatment: | India Sub-continent | % under 18: | 0 | | N entering: | Not reported
Study design: | Case series | % over 65: | Not reported | | N completing: | 30
Nanda | | Diagnosis: | Type 2 diabetes | 6 month or less | Arm 1: Nishamalaki, diet | | Outcomes: FBS
1998 | | Diagnostic criteria: | None described
Nishamalaki in Madhumeha (NIDDM): a clinical study | | | | | Plant part: | Not reported | FBS showed a reduction of 31–60 mg/dl in 40% of patients. There was significant symptomatic improvement with the drug, including polyuria and polydipsia.
| | % Female: | 20 | | Preparation: | Ayurvedic preparation
| | % under 18: | 0 | | N entering: | 100
Location of treatment: | India Sub-continent | % over 65: | Not reported | | N completing: | 100
Study design: | Case series
Jain | | Diagnosis | Type 2 diabetes | 6 months or less | Arm 1: Guar gum, Cephalandra indica, Gymnema sylvestre | | Arm 1 outcomes: Mean blood sugars, symptoms
1987 | | Diagnostic criteria | GTT
A clinical study on a herbal antidiabetic product, a preliminary report
| | % Female | 35 | | Plant part | N/A | In Arm 1, the mean blood sugar was reported to have reduced by 25–30%. Actual numerical values and statistical significance of these results were not reported. The authors also reported a marked reduction in symptoms in all cases as well as a decrease in the frequency and quantity of urine and a general sense of well being. No adverse effects were observed.
| | % under 18 | 0 | | Preparation | Ayurvedic preparation-granules
Location of treatment: | India Sub-continent | % over 65 | Not reported | | N entering | 15
Study design: | Case series | | | | N completing | 15
| | | | | Arm 2: Guar gum, Cephalandra indica, Gymnema sylvestre, oral hypoglycemic | | Arm 2 outcomes: Mean blood sugars, symptoms
| | | | | Plant part | N/A
| | | | | Preparation | Ayurvedic preparation- granules | In Arm 2 patients, there was a reduction of 50% in the mean blood sugar. Actual numerical values and statistical significance of these results were not reported. The authors also reported a marked reduction in symptoms in all cases as well as a decrease in the frequency and quantity of urine and a general sense of well being. No adverse effects were observed.
| | | | | N entering | 5
| | | | | N completing | 5
Sadhukhan | | Diagnosis: | Type 1 and type 2 diabetes | 6 months or less | Arm 1: Fenugreek, Gymnema sylvestre, guar gum, Cephalandra indica, diet | | Outcomes: FBS, PPBS reported for 11 out of the 25 patients as: FBS improved from 221.18 mg/dl to 211.8 mg/dl.
1994
Clinical evaluation of a herbal antidiabetic product. | | Diagnostic criteria: | FBS and GTT
| | | | | Plant part: | N/A
Location of treatment: | India Sub-continent | % Female: | 32 | | Preparation: | Not reported
Study design: | Case series | % under 18: | 0 | | N entering: | 25
| | % over 65: | Not reported | | N completing: | Not reported
Sadhukhan | | Diagnosis: | Type 2 diabetes | 6 months or less | Arm 1: Fenugreek, Gymnema sylvestre, guar gum, Cephalandra indica, diet | | Arm 1 outcomes: FBS, PPBS
1994 | | Diagnostic criteria: | FBS and GTT
Clinical evaluation of a herbal antidiabetic product. | | | | | | | FBS improved from 162.8 mg/dl to 157.95 mg/dl.
| | % Female | 29 | | Plant part: | N/A
Location of treatment: | India Sub-continent | % under 18 | 0 | | Preparation: | N/A
Study design: | Case series | % over 65: | 0 | | N entering: | Not reported
| | | | | N completing: | 42
| | | | | Arm 2: Guar gum, diet | | Arm 2 outcomes: FBS, PPBS
| | | | | Plant part: | N/A | FBS improved from 162.8 mg/dl to 155.61 mg/dl.
| | | | | Preparation: | Taken whole
| | | | | N entering: | Not reported
| | | | | N completing: | 42
| | | | | Arm 3: Fenugreek, diet | | Arm 3 outcomes: FBS, PPBS
| | | | | Plant part: | Seed | FBS improved from 162.8 mg/dl to 158.09 mg/dl.
| | | | | Preparation: | Taken whole
| | | | | N entering: | Not reported
| | | | | N completing: | 42
Sadhukhan | | Diagnosis: | Normal | 6 months or less | Arm 1: Fenugreek, Gymnema sylvestre, guar gum, Cephalandra indica, diet | | Arm 1 outcomes: FBS, PPBS
1994 | | Diagnostic criteria: | FBS and GTT
Clinical evaluation of a herbal antidiabetic product. | | | | | | | FBS increased from 84.83 mg/dl to 87.08 mg/dl.
| | % Female: | 33 | | Plant part: | N/A
Location of treatment: | India Sub-continent | % under 18: | Not reported | | Preparation: | 4 herbs
Study design: | Case series | % over 65: | Not reported | | N entering: | Not reported
| | | | | N completing: | 12
| | | | | Arm 2: Guar gum, diet | | Arm 2 outcomes: FBS, PPBS
| | | | | Plant part: | N/A | FBS increased from 84.83 mg/dl to 85.67 mg/dl.
| | | | | Preparation: | Taken whole, powder
| | | | | N entering: | Not reported
| | | | | N completing: | 12
| | | | | Arm 3: Fenugreek, diet | | Arm 3 outcomes: FBS, PPBS
| | | | | Plant part: | Seed | FBS increased from 84.83 mg/dl to 86.42 mg/dl
| | | | | Preparation: | Taken whole, powder
| | | | | N entering: | Not reported
| | | | | N completing: | 12
Acharya | | Diagnosis: | Normal and type 2 diabetes | 6 months or less | Series 1: Diet | | Series 1 outcomes: FBS, PPBS
1996
Dietary management in Prameha | | Diagnostic criteria: | Ayurvedic, FBS, GTT | | Plant part: | N/A | Outcomes not reportable
| | | | | Preparation: | n/a
Location of treatment: | India sub-continent | | | | N entering: | Not reported
Study design: | Case series | % Female: | Not reported | | N completing: | 7
| | % under 18: | Not reported | | Series 2: Diet, oral hypoglycemic, insulin | | Series 2 outcomes: FBS, PPBS
| | % over 65: | Not reported
| | | | | Plant part: | N/A | At 15 days FBS improved from 133 mg/dl to 123.5 mg/dl (p<0.001). PPBS improved from 236.3 mg/dl to 228.6 mg/dl (p<0.001).
| | | | | Preparation: | N/A
| | | | | N entering: | Not reported
| | | | | N completing: | 30
Pandya | | Diagnosis: | Type 1 and type 2 diabetes | 6 months or less | Arm 1: Diet | | Outcomes: GTT
1990
Role of Pathya Ahara in the treatment of Madhumeha, a clinical study | | Diagnostic criteria:Ayurvedic and FBS | | | Plant part: | N/A | The effect on GTT in Arm 1 before treatment was 169.3 mg/dl and 138.52 mg/dl after treatment, standard deviation 39.42 (p <0.05). All other measures in urinary and blood glucose measures for both groups didn't reach a statistical significance.
| | | | | Preparation: | N/A
| | % Female: | Not reported | | N entering: | N/A
Location of treatment: | India Sub-continent | % under 18: | Not reported | | N completing: | 5
Study design: | Case series | % over 65: | Not reported
| | | | | Arm 2: Ocimum sanctum, Banga Bhasma, diet | | Outcome: GTT
| | | | | | | FBS decreased from 238.25 mg/dl to 222.4 mg/dl; 2-hour PPBS decreased from 368.93 mg/dl to 317.43 mg/dl.
| | | | | Plant part: | Leaf
| | | | | Preparation: | N/A
| | | | | N entering: | N/A
| | | | | N completing: | 5
Kedar | | Diagnosis | Type 2 Diabetes | 6 months or less | Arm 1: Gurmar preparation formula | | Arm 1 outcomes: 2-hour post-prandial blood sugar, cholesterol and triglycerides
1981 | | Diagnostic criteria | GTT
Blood sugar, blood urea and serum lipids as influenced by Gurmar preparation, Pterocarpus marsupium and Tamarindus indica in diabetes mellitus | | | | | Plant part | Leaf and seed
| | % Female | Not reported | | Preparation | boiled and reduced | The gurmar treatment resulted in significant reductions in PPBS at 1, 2 and 3 weeks compared with initial pretreatment values (p<0.01). Beeja wood water also showed significant reductions for the same treatment periods (p<0.01). Tamarind seed treatment failed to show any significant reductions in PPBS levels. Serum lipid profiles were also positively affected by the three treatments as well. Gurmar preparation and beeja wood water resulted in significant reductions in triglyceride levels (p<0.01), while tamarind seed treatment resulted in significant reductions in total cholesterol, free fatty acid, and triglyceride levels (p<0.01).
| | % under 18 | 0 | | N entering | 10
| | % over 65 | 0 | | N completing | 10
Location of treatment: | India Sub-continent
Study design | RCT
Total Jadad score | 1
Randomized | Yes
Randomization appropriate | Not described
Double-blind | Not described
Blinding appropriate | Not described
Withdrawals/dropouts described | No
| | | | | Arm 2: Pterocarpus marsupium | | See Arm 1.
| | | | | Plant park | Bark
| | | | | Preparation | water from wood pot
| | | | | N entering | 10
| | | | | N completing | 8
| | | | | Arm 3: Tamarindus indica | | See Arm 1.
| | | | | Plant part | Seed
| | | | | Preparation | teesta of seeds
| | | | | N entering | 10
| | | | | N completing | 10

* NOTE: Chandola (1980a) presents three studies; one study appears in each Evidence Table and in “Characteristics of Studies Not Included in Further Analysis” in Appendix L.

RCT = randomized control trial; FBS = fasting blood sugar; UBS = urinary blood sugar; UCC = usual customary care; NS = not significant; CCT = clinical controlled trial; GTT = glucose tolerance test; PPBS = post-prandial blood sugar; N/A = not available / not applicable; Hg A_1c_ = hemoglobin A_1c_ ;HDL = high-density lipoprotein; LDL = low-density lipoprotein; VLDL = very low-density lipoprotein; TID = three times a day; SD = standard deviation