# Appendix K. Statistical Calculations Used for the Studies Selected for Further Analysis

This appendix describes our methods for extracting the data and estimating effect sizes and their confidence intervals. For each relevant study arm and outcome, we extracted the pre-intervention and post-intervention means and standard deviations or standard errors. We also extracted the sample size for the arm. If the sample sizes reported before and after the intervention disagreed, we chose the post-intervention sample size. This sample size was always the smaller and, therefore, had a conservative effect on our calculations.

The majority of the studies provided enough data to directly calculate the standard error of the difference in the pre- and post-intervention means. We required this standard error so that we could construct a confidence interval for the effect size.

Five studies provided patient-level data: Baskaran et al. (1990); Shanmugasundaram et al. (1990b); Chandola et al. (1980a), studies 1 and 2; and Sivaprakasam et al. (1984). For these studies we calculated our results directly rather than relying on reported summary statistics. The length of the confidence intervals for these studies should provide some guidance on how to interpret the other study results in Figures 1 and 2 (see Chapter 3).

In addition, for the three RCT/CCT studies that provided patient-level data (Baskaran et al. [1990], Shanmugasundaram et al. [1990b], and Chandola et al. [1980a], study 1), we conducted t-tests to determine if the comparison arms were really comparable pre-intervention. Those results are shown in the discussion of the individual articles.

Of the remaining studies,^5^ one provided the standard error of the difference (Chowdhary et al., 1998), and the rest provided a t-test statistic for the test of the difference in means from which we could back-calculate the standard error.

For the study by Azad Kahn et al. (1979), the post-prandial glucose standard error back-calculated from the reported t-statistic was much larger than that for any other study. Thus, we used the average correlation method to calculate this standard error as done for those studies that did not provide enough data to calculate a correlation.

We also utilized the studies that gave us data on the standard error of the mean difference to estimate the correlations between the pre- and post-intervention means for each of the three outcomes. We did this by equating the reported standard error for the mean difference with the formula for computing that standard error from the standard deviations of the means, from the sample size, and from the correlation, and then solving for the correlation. We averaged the observed correlations across the studies to arrive at estimated correlations for hemoglobin, fasting blood glucose, and post-prandial blood glucose.

For the studies that did not report a standard error for the mean difference, we used the appropriate estimated average correlation along with the reported standard deviations for the pre- and post-intervention means and the sample size to calculate the standard error of the mean difference. Other strategies we considered were to assume a correlation of zero, which seemed overly conservative, or to use the “rule-of-thumb” of assuming a correlation of 0.5 (Ray and Shadish, 1996).

For all studies, we first calculated a common “mean difference” statistic for each study arm. This statistic was the mean change in the outcome observed after the intervention; i.e., the difference in means calculated as the post-intervention mean minus the pre-intervention mean. Thus, a negative difference means that the average outcome dropped among the patients after the intervention and that the measures of diabetic severity (fasting blood sugar, hemoglobin _A1c_, and post-prandial blood sugar) improved.

For each RCT or CCT study with nonherbal comparison arm(s) in Evidence Table 1, we calculated a difference of differences as our effect size, which was equal to the treatment arm's post-intervention minus pre-intervention difference minus the control arm's post-intervention minus pre-intervention difference. We constructed a standard normal 95-percent confidence interval for this statistic using a variance estimate equal to the sum of the variances of the control and treatment arms' mean differences.

For each arm from studies with pre/post comparison data in Evidence Table 2, our effect size was the mean difference. For this estimate, we constructed a standard normal 95-percent confidence interval, using the standard deviation discussed previously.

The data we used in our calculations and the effect sizes displayed in Figures 1 and 2 of Chapter 3 are given in Appendix Tables 9–14.

Appendix Table 9. Data for Figure 1, left plot: Fasting blood sugar (mg/dl)

(Correlation estimate=0.60) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means** | Difference of differences**
RANDOMIZED CONTROLLED TRIALS
Azad Khan et al., 1979/Coccina indica (6 w) | 16 | 178.8 (50.6) | 122.1 (46.5) | -56.7 (16.3) | -42.6 (19.0)
Nonherbal comparison arm | 16 | 195.4 (51.9) | 181.3 (50.7) | -14.1 (9.7)
Agrawal et al., 1996 / Holy basil / (4 w) | 20 | 134.5 (23.4) | 99.7 (17.6) | -34.8 (4.3) | -25.6 (6.0)
Nonherbal comparison arm | 20 | 132.4 (22.0) | 123.2 (18.5) | -9.2 (4.2)
CONTROLLED CLINICAL TRIALS
Chandola et al., 1980a /C. tamala (1 m) | 32 | 153.4 (46.7) | 112.7 (41.9) | -40.8 (4.4) | -48.5 (13.2)
Nonherbal comparison arm | 8 | 156.4 (43.6) | 164.1 (61.1) | 7.7 (12.5)
Kamble et al., 1996 / Coccinia indica (6 w) | 25 | 160.0 (12.1) | 118.0 (11.1) | -42.0 (2.1) | 3.0 (4.9)
Nonherbal comparison arm | 15 | 165.0 (20.6) | 120.0 (16.3) | -45.0 (4.4)
Kohli and Singh, 1993/ E. jambolana (1 m) | 28 | 163.0 (81.3) | 129.6 (63.6) | -38.4 (8.0) | -12.8 (31.2)
Nonherbal comparison arm | 6 | 155.7 (73.6) | 130.0 (66.5) | -25.7 (30.2)
Baskaran et al., 1990 / Gymnema (8–10 m) | 22 | 174.5 (32.2) | 145.7 (26.6) | -28.8 (4.2) | -36.1 (4.9)
Nonherbal comparison arm | 25 | 150.0 (20.4) | 157.2 (21.1) | 7.3 (2.5)
Shanmugasundaram et al., 1990b/ Gymnema (6–8 m) | 27 | 231.9 (64.0) | 177.1 (75.2) | -54.8 (15.6) | -45.8 (17.7)
Nonherbal comparison arm | 37 | 233.1 (45.4) | 224.2 (1.7) | -8.9 (8.2)

* Mean with standard deviation in parentheses

** Mean with standard error in parentheses

Abbreviations: w=week; m=month

Appendix Table 10. Data for Figure 1, middle plot: Post-prandial blood glucose (mg/dl)

(Correlation assumed to equal 0.5) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means** | Difference of Differences**
RANDOMIZED CONTROLLED TRIALS
Azad Khan et al., 1979/Coccina indica (6 w) | 16 | 245.4 (41.4) | 186.9 (54.9) | -58.5 (12.4) | -55.4 (19.7)
Nonherbal comparison arm | 16 | 255.1 (58.6) | 252.0 (63.4) | -3.1 (15.3)
Agrawal et al., 1996 / Holy basil / (4 w) | 20 | 223.9 (19.9) | 204.0 (25.0) | -19.9 (5.1) | -13.4 (7.5)
Nonherbal comparison arm | 20 | 221.6 (20.1) | 215.1 (27.1) | -6.5 (5.4)
CONTROLLED CLINICAL TRIALS
Kamble et al., 1996 / Coccinia indica (6 w) | 25 | 308.0 (24.5) | 145.0 (14.1) | -163.0 (4.3) | -23.0 (7.8)
Nonherbal comparison arm | 15 | 292.0 (28.1) | 152.0 (20.2) | -140.0 (6.5)

* Mean with standard deviation in parentheses

** Mean with standard error in parentheses

Abbreviation: w=week

Appendix Table 11. Data for Figure 1, right plot: Hb A_1c_ (percent)

(Correlation estimate=0.44) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means** | Difference of differences**
CONTROLLED CLINICAL TRIALS
Baskaran et al., 1990 / Gymnema (8–10 m) | 22 | 11.91 (1.37) | 9.61 (1.01) | -2.30 (0.23) | -2.53 (0.27)
Nonherbal comparison arm | 25 | 10.22 (0.77) | 10.45 (0.71) | 0.23 (0.15)
Shanmugasundaram et al., 1990b/ Gymnema (6–8 m) | 27 | 12.81 (1.98) | 9.50 (1.73) | -3.31 (0.47) | -2.41 (0.60)
Nonherbal comparison arm | 37 | 12.68 (2.12) | 11.77 (2.41) | -0.90 (0.38)

*Mean with standard deviation in parentheses

**Mean with standard error in parentheses

Abbreviations: m=month; Hb=hemoglobin

Appendix Table 12. Data for Figure 2, left plot: Fasting blood sugar (mg/dl)

(Correlation estimate=0.67) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means**
SINGLE HERBS
Chandola et al.,1980a / C. tamala (1 m) | 25 | 144.9 (39.8) | 103.5 (30.8) | -41.3 (5.5)
Kamble et al., 1998/ Coccinia indica (6 w)*** | 15 | 365.0 (37.2) | 112.0 (11.6) | -253.0 (7.9)
Kuppurajan et al., 1986 / Coccinia indica (30 d) | 16 | 126.1 (44.0) | 117.3 (25.4) | -8.8 (8.2)
Kuppu Rajan et al., 1998 / Fenugreek (90 d) | 15 | 148.0 (64.6) | 128.3 (12.7) | -19.7 (14.0)
Kumar et al., 1999 / Fenugreek (6 w) | 51 | 174.6 (37.1) | 121.1 (26.6) | -53.6 (3.9)
Sharma et al., 1996a /Fenugreek (24 w) | 10 | 151.3 (17.1) | 111.7 (17.1) | -39.6 (4.4)
ICMR et al., 1998 / Pterocarpus (12 w) | 93 | 151.0 (17.3) | 119.0 (23.0) | -32.0 (2.6)
Goyal and Tiwari, 1999 / 2Vinca rosea (30 d) | 25 | 131.4 (30.2) | 92.0 (18.2) | -39.4 (4.9)
MIXED HERBS
Chowdhary et al., 1998 / Ayush-82 (6 w) | 89 | 169.3 (not given) | 144.2 (not given) | -25.1 (3.5)
Kumar et al., 1999 / Ayush-82 (6 w) | 30 | 169.2 (32.8) | 120.9 (24.5) | -48.3 (3.8)
Pandey, et al., 1995 / Ayush-82 (12 w) | 80 | 193.1 (48.6) | 135.8 (41.4) | -57.4 (4.1)
Kumar et al., 1999 / Abraga chandraprabhavati, etc. (6 w) | 30 | 168.3 (28.5) | 119.2 (31.3) | -49.1 (4.6)
Shankar and Singhal, 1995 / Chendooram (45 d) | 130 | 172.3 (55.0) | 110.0 (43.4) | -62.3 (3.6)
Maji and Singh, 1995 / D-400 (6 m) | 19 | 208.5 (12.1) | 113.1 (6.9) | -95.4 (2.1)
Sircar et al., 1996 / MA-471 (3 m)-Uncontrolled min dose | 15 | 167.2 (22.0) | 131.1 (20.0) | -36.0 (4.4)
Sircar et al., 1996 / MA-471 (3 m)-Controlled | 30 | 115.8 (20.5) | 106.3 (24.3) | -9.5 (3.4)
Sircar et al., 1996 / MA-471 (3 m)-Uncontrolled max dose | 15 | 150.2 (21.8) | 110.6 (19.3) | -39.6 (4.3)
Shankar and Singhal, 1994 / Sandana podi-a (45 d) | 20 | 164.5 (60.2) | 114.7 (40.2) | -49.8 (7.6)

*Mean with standard deviation in parentheses

**Mean with standard error in parentheses

***This study does not appear in Figure 2 due to its large effect size.

Abbreviations: d=day; w=week; m=month; min=minimum; max=maximum; ICMR=Indian Council for Medical Research

Appendix Table 13. Data for Figure 2, middle plot: Post-prandial blood glucose (mg/dl)

(Correlation estimate=0.62) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means**
SINGLE HERBS
Chandola et al., 1980a / C. tamala (1 m) | 25 | 236.2 (72.1) | 170.6 (54.7) | -65.6 (7.4)
Kuppurajan et al., 1986 / Coccinia indica (30 d) | 16 | 233.1 (107.2) | 197.7 (23.3) | -35.4 (23.6)
Kuppu Rajan, et al., 1998 / Fenugreek (90 d) | 15 | 314.3 (25.2) | 264.8 (21.3) | -49.5 (19.2)
Kumar et al., 1999 / Fenugreek (6 w) | 51 | 236.5 (39.2) | 183.8 (16.9) | -52.7 (4.9)
Sharma et al., 1996a / Fenugreek (24 w) | 10 | 257.6 (34.2) | 171.1 (34.2) | -86.5 (9.4)
ICMR et al., 1998 / Pterocarpus (12 w) | 93 | 216.0 (21.5) | 171.0 (29.1) | -45.0 (3.1)
Goyal and Tiwari, 1999 / Vinca rosea (30 d) | 25 | 224.9 (22.5) | 144.2 (27.3) | -80.7 (6.4)
MIXED HERBS
Chowdhary et al., 1998 / Ayush-82 (6 w) | 89 | 249.6 (not given) | 219.2 (not given) | -30.4 (5.5)
Kumar et al., 1999 / Ayush-82 (6 w) | 30 | 218.4 (38.6) | 172.9 (34.2) | -45.5 (3.7)
Pandey, et al., 1995 / Ayush-82 (12 w) | 80 | 283.7 (91.2) | 202.6 (45.9) | -81.2 (8.1)
Kumar et al., 1999 /Abraga chandraprabhavati, etc. (6 w) | 30 | 234.1 (43.3) | 181.8 (14.0) | -52.2 (6.4)
Shankar and Singhal, 1995 / Chendooram (45 d) | 140 | 267.7 (73.5) | 183.0 (63.1) | -84.7 (5.1)
Maji and Singh, 1995 / D-400 (6 m) | 19 | 262.0 (20.1) | 141.2 (8.3) | -120.8 (3.7)
Sircar et al., 1996 /MA-471 (3 m)-Uncontrolled min dose | 15 | 290.0 (28.3) | 230.9 (23.1) | -59.1 (5.9)
Sircar et al., 1996 /MA-471 (3 m)-Controlled | 30 | 172.0 (19.3) | 163.9 (18.4) | -8.1 (3.0)
Sircar et al., 1996 /MA-471 (3 m)-Uncontrolled max dose | 15 | 247.3 (22.3) | 186.1 (18.0) | -61.3 (4.6)
Shankar and Singhal, 1994 / Sandana podi-a (45 d) | 20 | 281.7 (95.7) | 171.3 (72.2) | -110.5 (17.0)
Sivaprakasam, et al., 1984 / Shudh Shilajitu (90 d) | 25 | 303.9 (88.4) | 208.1 (77.8) | -95.8 (13.6)

*Mean with standard deviation in parentheses

**Mean with standard error in parentheses

Abbreviations: d=day; w=week; m=month; min=minimum; max=maximum; ICMR=Indian Council for Medical Research

Appendix Table 14. Data for Figure 2, right plot: Hb A_1c_ (percent)

(Correlation assumed to equal 0.50) | Sample size | Pre-Intervention mean* | Post-Intervention mean* | Difference of means**
SINGLE HERBS
Sharma et al., 1996a /Fenugreek (8 w) | 10 | 9.60 (1.90) | 8.40 (1.40) | -1.20 (0.54)
ICMR et al., 1998 / Pterocarpus (12 w) | 67 | 9.80 (1.00) | 9.40 (0.90) | -0.40 (0.15)
MIXED HERBS
Sircar et al., 1996 / MA-471 (3 m)-Uncontrolled min dose | 15 | 10.30 (2.80) | 8.50 (1.49) | -1.80 (0.63)
Sircar et al., 1996 / MA-471 (3 m)-Controlled | 30 | 7.00 (1.97) | 7.10 (2.10) | 0.10 (0.37)
Sircar et al., 1996 / MA-471 (3 m)-Uncontrolled max dose | 15 | 10.10 (2.50) | 8.00 (1.70) | -2.10 (0.57)

*Mean with standard deviation in parentheses

**Mean with standard error in parentheses

Abbreviations: w=week; m=month; min=minimum;max=maximum; Hb=hemoglobin; ICMR=Indian Council for Medical Research