# Appendixes

Appendix A. Ayurveda's History, Beliefs and Practices

Appendix B. Acknowledgments

Appendix C. Search Methodology for Ayurveda

Appendix D. Ayurveda Abstract Screening Form

Appendix E. List of Interviewees

Appendix F. Questions for the Structured Interview

Appendix G. Core Journals at the Central Council for Research in Ayurveda and Siddha Library

Appendix H. List of Documents Received From India

Appendix I. Quality Review Form

Appendix J. Supplemental Quality Review Form

Appendix K. Statistical Calculations Used for the Studies Selected for Further Analysis

Appendix L. Studies Not Included in Further Analysis