# Acknowledgments

## Reviewers

We gratefully acknowledge the following individuals who reviewed the initial daft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- *Betty L. Chang, DNSc, FNP-C, FAAN
  * Also member of the technical expert panel
- Professor, School of Nursing,
- University of California, Los Angeles
- Los Angeles, CA

- *Francesco Chiappelli, PhD
- Laboratory of Human Oral & MolecularImmunology, School of Dentistry
- University of California, Los Angeles
- Los Angeles, CA

- *David Diehl, MD
- Associate Clinical Professor of Medicine
- Western Gastroenterologists Inc
- Irvine, CA

- Douglas Drossman, MD
- UNC School of Medicine, Division ofDigestive Diseases and Nutrition,
- University of North Carolina
- Chapel Hill, North Carolina

- William L. Haskell, PhD
- Professor of Medicine, Stanford Centerfor Research in Disease Prevention
- Palo Alto, CA

- James D. Lane, MD
- Department of Psychiatry andBehavioral Sciences,
- Duke University Medical Center
- Durham, NC

- Suzanne Little, PhD
- Coordinator, Mind-Body Program,
- Center for Health and Healing
- Beth Israel Medical Center
- New York, NY

- Emeran Mayer, MD
- University of California, Los Angeles/
- Cure Neuroenteric Disease Program
- VA Greater Los Angeles Healthcare System
- Los Angeles, CA

- Joshua Ofman, MD, MSHS
- Zynx Health Incorporated
- Beverly Hills, CA

- Kenneth R. Pelletier, PhD, MD, Chc
- Director
- Stanford Corporate Health Program
- Palo Alto, CA

- *David Riley, MD
- Clinical Associate Professor, Universityof North West Medical School
- Editor, Alternative Therapies in Healthand Medicine,
- Director, Integrative Medicine Research
- Santa Fe, NM

- Sara L. Warber, MD
- Co-Director, University of MichiganComplementary and Alternative MedicineResearch Center
- University of Michigan
- Ann Arbor, MI

## Technical Expert Panel

We also wish to acknowledge the work of our technical expert panel. In addition to the four members who also acted as reviewers (see preceding page), the panel included the following individuals:

- Seigward-Markus Elsas, MD
- Clinical Fellow in Neurophysiology,
- University of California, Los Angeles
- Los Angeles, CA

- Glenn Clark, DDS
- School of Dentistry
- University of California, Los Angeles
- Los Angeles, CA

- Deborah Glik, PhD
- Associate Professor, School of Public Health
- University of California, Los Angeles
- Los Angeles, CA

- Michael Goldstein, PhD
- Professor, School of Public Health
- University of California, Los Angeles
- Los Angeles, CA

- Eric Hurwitz, DC, PhD
- Assistant Professor, Department ofEpidemiology, School of Public Health
- University of California, Los Angeles
- Los Angeles, CA

- Ka Kit Hui, MD, FACP
- Professor, UCLA School Medicine,
- Director, UCLA Center for East-West Medicine
- University of California, Los Angeles
- Los Angeles, CA

- Simon Mills, MA, MCPP, FNIMH
- Director for the Center of ComplementaryMedicine
- University of Exeter
- Exeter, England

- Lakshmi C. Mishra, MD, PhD
- Research
- Los Angeles College of Chiropractic
- Whittier, CA

- Shri K. Mishra, MD, MS
- Doctor of Ayurveda,
- Professor of Neurology/IntegrativeMedicine, Institute for Health Promotionand Disease Prevention Research,
- USC School of Medicine
- University of Southern California
- Los Angeles, CA

- Lucy Postolov, LAc
- Postolova Acupuncture Group
- Los Angeles, CA

- Betsy B Singh, PhD
- Dean of Research
- Los Angeles College of Chiropractic
- Whittier, CA

- George Solomon, MD
- Professor Emeritus, UCLA School ofMedicine, Dept. Psychiatry andBiobehavioral Medicine
- University of California, Los Angeles
- Los Angeles, CA

- Hitoshi Tomizawa, MD
- Director, Japanese Executive MedicalServices, Cedars-Sinai Medical Center
- Los Angeles, CA

- Xiao-Ping Xu, LAc
- Burns and Allen Research Institute
- Cedars Sinai Medical Center
- Los Angeles, CA

## Translators

We also wish to acknowledge the assistance of the following who provided assistance in translating articles.

- Dr. Mary Hardy
- French

- Dr. Francesco Chiappelli
- Italian, Spanish

- Dr. Lucy Postolov
- Russian

- Ms Kyra Kneis
- German

- Dr. Seigward Elsas
- German