# Evidence Tables

Evidence Table

Title Authors Year of publication Study design | Conditions studied Study population Time at followup | Study quality | Interventions | Outcomes
Biofeedback for the treatment of fecal incontinence. Long-term clinical results. Guillemot et al, 1994 CCT | Incontinence More than 6 months | | | Measures: bowel movements and manometry. The BF group incontinence score was significantly lower at 6 months than the non-BF group but not as low at 30 months as at 6 months. BF impact deteriorates over time.
  % Female: | 56
  % under 18: | 0
  % over 65: | 33
  Total Jadad score: | 1
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  None checked
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
  ..............................................
  Biofeedback
  N entering: | 18
  N completing: | 16
  Setting: | Hospital
  ..............................................
  Medical treatment
  N entering: | 10
  N completing: | 8
  Setting: | Hospital
Investigation of mode of action of biofeedback in treatment of fecal incontinence. Miner et al, 1990 RCT | Incontinence More than 6 months | | | Measures: degree of fecal incontinence, manometry Overall, biofeedback with active sensory retraining reduced frequency of fecal incontinence compared with sham retraining.
  % Female: | 68
  % under 18: | 0
  % over 65: | 16
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Sham sensory training
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
  ..............................................
  Biofeedback (active sensory retraining)
  N entering: | 13
  N completing: | 13
  Setting: | Hospital
  ..............................................
  Biofeedback (coordination training)
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Hospital
  ..............................................
  Biofeedback (strength training)
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Hospital
Fecal incontinence - a controlled trial of biofeedback McHugh et al, 1986 RCT | Incontinence Not reported | | | Measures: manometry, fecal incontinence, fecal staining, number of bowel movements Overall, no significant difference in biofeedback vs. voluntary sphincter exercise protocol (UCC)
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (exercise)
  N entering: | 18
  N completing: | 18
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 18
  N completing: | 18
  Setting: | Hospital
Controlled randomised trial of visual biofeedback versus muscle training without a visual display for intractable constipation. Koutsomanis et al, 1995 RCT | Constipation More than 6 months | | | Measures: EMG, defecation dynamics, bowel movement and stools, pain, symptoms. Symptom improvement in BF group 14/31 (45%) and UCC 12/28 (43%) and in pelvic floor muscle activity. No difference between the groups. BF adds nothing.
  % Female: | 88
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | No
  Blinding appropriate: | Not applicable
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 30
  N completing: | 28
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 29
  N completing: | 31
  Setting: | Hospital
Biofeedback treatment for chronic constipation and encopresis in childhood: long-term outcome. Loening-Baucke, 1995 RCT | Constipation, incontinence More than 6 months | | | Measures: manometry, quality of stools, fecal incontinence, medication use, pain, defecation dynamics, urinary incontinence Learning normal defecation dynamics did not increase long-term recovery rates in biofeedback compared with customary care.
  % Female: | 48
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 66
  N completing: | 66
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 63
  N completing: | 63
  Setting: | Hospital
Does biofeedback treatment of anismus improve longterm outcome in constipation? Loening-Baucke, 1994 CCT | Constipation More than 6 months | | | Measures: number of bowel movements, number of fecal soiling Overall, all three groups had similar improvements in recovery rates.
  % Female: | Not reported
  % under 65: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 0
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 86
  N completing: | 86
  Setting: | Hospital
  ..............................................
  UCC
  N entering: | 66
  N completing: | 66
  Setting: | Hospital
  ..............................................
  Cognitive
  N entering: | 63
  N completing: | 50
  Setting: | Hospital
Evaluation of biofeedback in childhood encopresis. Wald et al, 1987 RCT | Incontinence More than 6 months | | | Measures: manometry, defecation dynamics, frequency of defecation, fecal incontinence Overall, no significant difference in clinical outcomes between groups.
  % Female: | 20
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 26
  N completing: | 25
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 24
  N completing: | 23
  Setting: | Hospital
Randomised controlled trial of biofeedback training in persistent encopresis with anismus. Nolan et al, 1998 RCT | Constipation, incontinence 6 months or less | | | Measures: manometry, radiographs, EMG, defecation, defecation dynamics, behavior, use of laxatives. At six months (2/14 (14%) of BF group were laxative free and 2/15 (13%) of the control group were. No significant difference in behavioral scores. BF significantly better in school scale scores. BF provides no lasting benefit.
  % Female: | 7
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | No
  Blinding appropriate: | Not applicable
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 14
  N completing: | 13
  Setting: | Hospital
Biofeedback training in treatment of childhood constipation: a randomised controlled study. van,der Plas et al, 1996 RCT | Constipation More than 6 months | | | Measures: defecation dynamics, manometry, laxative use Despite improvements in normal dafaecation dynamics in biofeedback group, there were no differences in clinical outcomes.
  % Female: | 44
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 94
  N completing: | 91
  Setting: | Hospital
  ..............................................
  Biofeedback
  N entering: | 98
  N completing: | 96
  Setting: | Hospital
Randomised trial of biofeedback training for encopresis. van der Plas et al, 1996 RCT | Incontinence More than 6 months | | | Measures: bowel movements, use of laxatives, manometry, EMG, behavior, abdominal exam, rectal exam. Children given laxatives plus BF had higher success rate initially than laxatives alone (39% vs. 19%), but at 12 and 18 months, 50% in both groups were successful. BF had no additional benefit.
  % Female: | 33
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (laxatives)
  N entering: | 32
  N completing: | 32
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC
  N entering: | 39
  N completing: | 39
  Setting: | Hospital
Biofeedback training for children with recurrent abdominal-pain. Benninga et al, 1996 RCT | Abdominal pain 6 months or less | | | Measures: pain, use of laxatives, manometry Overall, biofeedback had no additional value to usual and customary care.
  % Female: | 45
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Biofeedback
  N entering: | 14
  N completing: | 14
  Setting: | Hospital
Biofeedback for anismus in 15 sexually abused women. Leroi et al, 1996 CCT | Abdominal pain, constipation, diarrhea, incontinence, IBS More than 6 months | | | Measures: anal pressure, EMG, symptoms. Total recovered completely 6/13 (46%): one in the biofeedback only group; three in the biofeedback and group therapy group; and two in the biofeedback and individual psychotherapy group.
  % Female: | 100
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Biofeedback
  N entering: | 7
  N completing: | 5
  Setting: | Hospital
  ..............................................
  Biofeedback and group therapy
  N entering: | 5
  N completing: | 5
  Setting: | Hospital
  ..............................................
  Biofeedback and individual psychotherapy
  N entering: | 3
  N completing: | 3
  Setting: | Hospital
Biofeedback retraining in patients with functional constipation and paradoxical puborectalis contraction: comparison of anal manometry and sphincter electromyography for feedback. Glia et al, 1997 RCT | Constipation 6 months or less | | | Measures: manometry, EMG, defecation dynamics, transit time fluoroscopy. Abnormal contraction disappeared from manometry BF in 8/10 (80%) and 10/10 for the EMG FB group. At 6 months 6/10 (60%) of the manometry BF and 9/10 (90%) of the EMG BF had improved symptoms
  % Female: | 88
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Biofeedback (manometry)
  N entering: | 13
  N completing: | 10
  Setting: | Hospital/Home
  ..............................................
  Biofeedback (EMG)
  N entering: | 13
  N completing: | 10
  Setting: | Clinic/Home
Prospective, randomized trial comparing four biofeedback techniques for patients with constipation. Heymen et al, 1999 RCT | Constipation Not reported | | | Measures: EMG, defecation dynamics, bowel movements, use of cathartics. Statistically significant improvement for bowel movements in Groups 1, 2, and 4. Reduction in cathartics for Groups 1, 2, and 3. No significant differences among the treatments. BF alone (Group 1) is as effective as the combination.
  % Female: | 100
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Biofeedback, education, and pelvic floor exercises (Group 1)
  N entering: | 9
  N completing: | 9
  Setting: | Hospital
  ..............................................
  Biofeedback, balloon sensory, education, and pelvic floor exercises (Group 2)
  N entering: | 9
  N completing: | 9
  Setting: | Hospital
  ..............................................
  Biofeedback, education, pelvic floor exercises, and home trainer (Group 3)
  N entering: | 8
  N completing: | 8
  Setting: | Hospital
  ..............................................
  Behavioral education, exercise, balloon sensory, and home trainer (Group 4)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Fynes et al, 1999 RCT | Incontinence 6 months or less | | | Measures: manometry, symptoms, EMG, anal endosonograph. Significant improvement in fecal incontinence scores in both groups but augmented BF was superior (15/20 (5%)) became asymptomatic vs. 7/19 (37%) in the sensory BF.
  % Female: | 100
  % under 18: | Not reported
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | No
  Blinding appropriate: | Not applicable
  Withdrawals/dropouts described: | Yes
  Biofeedback (sensory)
  N entering: | 20
  N completing: | 19
  Setting: | Hospital
  ..............................................
  Biofeedback (augmented)
  N entering: | 20
  N completing: | 20
  Setting: | Hospital
Biofeedback treatment of constipation: a comparison of two methods. Bleijenberg et al, 1994 RCT | Constipation More than 6 months | | | Measures: EMG readings, self-observation diary, psychological symptoms, physical symptoms (constipation, defecation frequency, incomplete defecation), pain, use of laxatives Overall, 8/11 patients in the EMG biofeedback had improved compared with 2/9 patients in the balloon biofeedback group.
  % Female: | 76
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Biofeedback (EMG)
  N entering: | 11
  N completing: | 11
  Setting: | Hospital
  ..............................................
  Biofeedback (Balloon)
  N entering: | 10
  N completing: | 9
  Setting: | Hospital
A comparison of biofeedback and stress management in the control of irritable bowel syndrome. Welgan et al, 1986 CCT | IBS Not reported | | | Measures: EMG, galvanic skin responses, bowel sounds, pain Overall, biofeedback and stress management significantly reduced central and autonomic arousal states.
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 0
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Biofeedback stress management and assignments
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Not described
  ..............................................
  Biofeedback stress management and contingent assignments
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Not described
Hypnotherapy in severe refractory irritable-bowel syndrome. Whorwell et al, 1984 RCT | IBS 6 months or less | | | Measures: symptoms, pain, absominal distention, sense of well-being, bowel habits Overall, the hypnosis patients had improvement in bowel habit, abdominal distention, and sense of well being which reached statistical significance.
  % Female: | 87
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Hypnosis and UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
Controlled trial of hypnotherapy in relapse prevention of duodenal ulceration. Colgan et al, 1988 RCT | Peptic ulcer disease More than 6 months | | | Measures: endoscopic evaluation Overall, at 1 year follow-up, there was a statistically significant difference in relapse rates: 53% for hypnosis vs. 100% control (UCC).
  % Female: | 47
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Hypnosis and UCC
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
Hypnotherapy for control of anticipatory nausea and vomiting in children with cancer - preliminary findings. Hawkins et al, 1995 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea and vomiting Overall, the number of vomiting episodes decreased by 33% in hypnosis training group and by 11% in the therapist contact group
  % Female: | 60
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  UCC (hypnosis training group)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  UCC (therapist contact group)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
A randomized, controlled-study of hypnotic and nonhypnotic behavioral intervention for chemotherapy-related nausea and vomiting. Zeltzer et al, 1987 RCT | Nausea and Vomiting Not reported | | | Measures: nausea, vomiting, tolerability of chemotherapy Overall, nausea and vomiting were significantly reduced for the hypnosis group.
  % Female: | Not reported
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Hospital
  ..............................................
  Support group
  N entering: | Not reported
  N completing Not reported
  Setting: | Hospital
  ..............................................
  Hypnosis
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Hospital
Hypnotic suggestions and imaginations in the treatment of colitis ulcerosa. Schmidt 1992 RCT | Ulcerative colitis More than 6 months | | | Measures: number of relapses, necessity of surgical interventions, repeated inflammation Overall, all patients in hypnosis group were relapse-free after 50 months, while no one in the control group showed any continual improvement.
  % Female: | 60
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 18
  N completing: | 18
  Setting: | Hospital
  ..............................................
  Hypnosis
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
The treatment of irritable bowel syndrome with hypnotherapy. Galovski et al, 1998 RCT | IBS 6 months or less | | | Measures: psychological tests, susceptibility to hypnosis, symptoms. Overall, symptoms improved significantly, and anxiety scores decreased in the hypnosis group.
  % Female: | 83
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Symptom monitoring
  N entering: | 6
  N completing: | 5
  Setting: | Hospital
  ..............................................
  Hypnosis
  N entering: | 6
  N completing: | 6
  Setting: | Hospital
Hypnosis not directed at specific symptoms fails to improve irritable bowel symptoms. Anton 1997 | Inflammatory bowel disease Not reported | | | Measures: pain, number of bowel movements, quality of life Overall, no significant differences in symptoms between groups. The quality of life score showed an increase for hypnosis group.
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 10
  N completing: | 7
  Setting: | Hospital
  ..............................................
  Hypnosis and UCC
  N entering: | 11
  N completing: | 11
  Setting: | Hospital
Hypnotherapy for irritable bowel syndrome (ibs) - a blinded randomised controlled trial. Forbes et al, 1999 RCT | IBS 6 months or less | | | Measures: symptoms Overall, symptom scores fell in 76% of the subjects in the hypnotherapy group vs. 56% in the audiotape group
  % Female: | 71
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | No
  Blinding appropriate: | Not applicable
  Withdrawals/dropouts described: | Yes
  Hypnosis (hypnotherapy)
  N entering: | 25
  N completing: | 25
  Setting: | Hospital
  ..............................................
  Hypnosis (audio tape)
  N entering: | 27
  N completing: | 27
  Setting: | Hospital
Systematic desensitization versus relaxation training and no treatment (controls) for the reduction of nausea, vomiting and anxiety resulting from chemotherapy. Meyer 1983 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea, vomiting, anxiety Overall, both desensitization and relaxation were effective against nausea and anxiety and somewhat effective against vomiting; desensitization was more beneficial.
  % Female: | 68
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not applicable
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 12
  N completing: | 12
  Setting: | Private clinic
  ..............................................
  Relaxation and UCC
  N entering: | 12
  N completing: | 12
  Setting: | Private clinic | ..............................................
  UCC (systematic desensitization)
  N entering: | 13
  N completing: | 13
  Setting: | Private clinic
Separate and combined effects of biofeedback training and brief individual psychotherapy in the treatment of gastrointestinal disorders. Giles 1978 RCT | GI non-specific More than 6 months | | | Measures: symptoms, psychological scales, psychiatric scales, consistency of bowel movements, nausea Overall, biofeedback/relaxation group had better measures of loose bowel movements, and nausea. Psychological symptoms were improved most with the combined treatment (biofeedback, relaxation and psychotherapy) group.
  % Female: | 50
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 10
  N completing: | 10
  Setting: | Community and Hospital
  ..............................................
  Psychotherapy
  N entering: | 10
  N completing: | 10
  Setting: | Community and Hospital
  ..............................................
  Biofeedback and relaxation
  N entering: | 10
  N completing: | 10
  Setting: | Community and Hospital
  ..............................................
  Biofeedback, relaxation, and psychotherapy
  N entering: | 10
  N completing: | 10
  Setting: | Community and Hospital
Relaxation training as a treatment for chronic pain caused by ulcerative colitis. Shaw et al, 1987 RCT | Ulcerative colitis 6 months or less | | | Measures: self-reports of pain, use of pain medications, and distress Overall, the relaxation group was significantly improved compared with control group.
  % Female: | 50
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 20
  N completing: | 20
  Setting: | Community
  ..............................................
  Relaxation and UCC
  N entering: | 20
  N completing: | 20
  Setting: | Hospital
Relaxation training as a treatment for irritable bowel syndrome. Blanchard et al, 1993 RCT | IBS More than 6 months | | | Measures: physical exam, symptoms, pain, constipation, diarrhea, etc., psychological assessment. Relaxation group showed significantly more improvement, symptoms reduction (50% vs. 13%).
  % Female: | 75
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | No
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC and monitoring
  N entering: | 9
  N completing: | 8
  Setting: | Hospital
  ..............................................
  Relaxation
  N entering: | 14
  N completing: | 8
  Setting: | Hospital
A physical relaxation technique reduces psychological stress and improves quality-of-life in patients with irritable-bowel-syndrome Hentschel et al, 1994 RCT | IBS 6 months or less | | | Measures: abdominal complaints, symptoms Overall, relaxation group was significantly better than placebo group in terms of reduced physical and mental stress in coping, general well being, satisfaction with activities of daily living, and global life satisfaction.
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Placebo
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Not described
  ..............................................
  Relaxation
  N entering: | Not reported
  N completing: | Not reported
  Setting: | Not described
Effectiveness of progressive muscle relaxation in reducing nausea, vomiting, and anxiety induced by chemotherapy in Japanese patients. Arakawa, 1995 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea, vomiting, anxiety Overall, progressive muscle relaxation reduced total scores for nausea, vomiting and anxiety compared with control.
  % Female: | 40
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 30
  N completing: | 30
  Setting: | Hospital
  ..............................................
  Relaxation
  N entering: | 30
  N completing: | 30
  Setting: | Hospital
Matching treatment with recurrent abdominal pain symptoms: An evaluation of dietary fiber and relaxation treatments. Edwards et al, 1991 CCT | Abdominal pain and constipation 6 months or less | | | Measures: pain, disruption of social functioning, symptoms. Overall, those with symptoms of constipation improved but in only one subject (9%) did relaxation have any specific effect.
  % Female: | 64
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 0
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Diet-fiber
  N entering: | 4
  N completing: | 4
  Setting: | Hospital/Home
  ..............................................
  Relaxation and diet-fiber
  N entering: | 7
  N completing: | 7
  Setting: | Hospital/Home
Ineffectiveness of relaxation on vomiting induced by cancer chemotherapy. Holli 1993 RCT | Vomiting 6 months or less | | | Measures: vomiting, tolerability of chemotherapy Overall, no significant difference in tolerability of chemotherapy or vomiting.
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 24
  N completing: | 24
  Setting: | Hospital
  ..............................................
  Relaxation and UCC
  N entering: | 43
  N completing: | 43
  Setting: | Hospital
Contribution of behavior therapy and biofeedback to laxative therapy in the treatment of pediatric encopresis. Cox et al, 1998 RCT | Incontinence 6 months or less | | | Measures: bowel movements, manometry, pain, cathartics, and psychological tests. Enhanced toilet training (ETT) and the biofeedback, ETT and IMC combined treatment group produced similar reduction in soiling (76% and 65%) that were superior to intensive medical care (21%). ETT employed fewer laxatives, had fewer treatments, and lower cost.
  % Female: | Not reported
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Intensive medical care (IMC)
  N entering: | 29
  N completing: | 29
  Setting: | Hospital
  ..............................................
  Enhanced toilet training (ETT)
  N entering: | 27
  N completing: | 27
  Setting: | Hospital
  ..............................................
  Biofeedback, ETT, and IMC
  N entering: | 31
  N completing: | 31
  Setting: | Hospital
The effectiveness of behavioral intervention for reduction of nausea and vomiting in children and adolescents receiving chemotherapy. Zeltzer et al, 1984 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea, vomiting Overall, nausea and vomiting were improved with both supportive counseling and hypnosis
  % Female: | Not reported
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (supportive counseling)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  Hypnosis and UCC
  N entering: | 9
  N completing: | 9
  Setting: | Hospital
Behavioral treatment for the anticipatory nausea and vomiting induced by cancer chemotherapy. Morrow et al, 1982 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea, vomiting Overall, there was a significant reduction in anticipatory nausea before 5^th^ and 6^th^ chemotherapy treatments with the desensitization group than those who received counseling or no treatment.
  % Female: | 70
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Behavioral and UCC (desensitization)
  N entering: | 20
  N completing: | 20
  Setting: | Hospital
  ..............................................
  UCC (counseling)
  N entering: | 20
  N completing: | 20
  Setting: | Hospital
  UCC (no treatment)
  N entering: | 20
  N completing: | 20
  Setting: | Hospital
Cognitive-behavioral treatment of recurrent nonspecific abdominal pain in children: an analysis of generalization, maintenance, and side effect. Sanders, et al. 1989 RCT | Abdominal pain 6 months or less | | | Measures: pain Overall, both cognitive-behavioral and the control (UCC) groups reduced their pain, the cognitive behavioral group improved more quickly.
  % Female: | Not reported
  % under 65: | 100
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 8
  N completing: | 8
  Setting: | Hospital
  ..............................................
  Behavioral and cognitive
  N entering: | 8
  N completing: | 8
  Setting: | Hospital
Stress management for irritable bowel syndrome: a controlled trial. Shaw et al, 1991 RCT | IBS More than 6 months | | | Measures: symptoms Overall, 67% of patients in stress management group rated the program effective in relieving symptoms compared with 18% of the control (UCC alone) group.
  % Female: | 57
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 17
  N completing: | 17
  Setting: | Hospital
  ..............................................
  UCC (stress management)
  N entering: | 18
  N completing: | 18
  Setting: | Hospital
Cognitive therapy for irritable bowel syndrome. Greene et al, 1994 RCT | IBS 6 months or less | | | Measures: GI symptoms Overall, at post-treatment 80% of cognitive therapy showed clinically significant improvement vs. only 10% of the control (symptom monitoring) group.
  % Female: | 75
  % under 65: | 0
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Symptom monitoring
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  Cognitive therapy
  N entering: | 10
  N completing: | 6
  Setting: | Hospital
Randomised trial of laxatives in treatment of childhood encopresis. Nolan et al, 1991 RCT | Incontinence More than 6 months | | | Measures: radiographs to assess constipation, child behavior Overall, a significant difference in patient groups achieving remission in the combined therapy (51%) vs. behavior therapy alone (36%).
  % Female: | 27
  % under 65: | 100
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Behavioral
  N entering: | 86
  N completing: | 86
  Setting: | Hospital
  ..............................................
  Behavioral and laxatives
  N entering: | 83
  N completing: | 83
  Setting: | Hospital
Stress and contingency management in the treatment of irritable bowel syndrome. Fernandez et al, 1998 RCT | IBS More than 6 months | | | Measures: IBS symptom diary Overall, the subjects who received training in contingency management experienced significant reductions in all characteristic digestive symptoms
  % Female: | 66
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 4
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Yes
  Blinding appropriate: | Yes
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 23
  N completing: | 21
  Setting: | Hospital
  ..............................................
  Behavioral (placebo)
  N entering: | 23
  N completing: | 7
  Setting: | Hospital
  ..............................................
  Behavioral (stress management)
  N entering: | 21
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Behavioral (contingency management)
  N entering: | 23
  N completing: | 16
  Setting: | Hospital
A controlled behavioral study of irritable bowel syndrome. Lynch et al, 1989 RCT | IBS 6 months or less | | | Measures: patient diaries including pain, discomfort, diarrhea, and constipation Remediation of irritable bowel syndrome symptoms and improvement in mood and self-perception after treatment. Therapeutic gains maintained five months after treatment.
  % Female: | 66
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (wait listed for treatment)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  Behavioral
  N entering: | 11
  N completing: | 11
  Setting: | Hospital
A controlled comparison of cognitive therapy and self-help support groups in the treatment of irritable-bowel-syndrome. Payne et al, 1995 RCT | IBS 6 months or less | | | Measures: GI symptoms, index for symptom change, psychological measurements Overall, cognitive therapy group had significant reductions in symptoms compared with support group and control (UCC alone).
  % Female: | 85
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  UCC (support group)
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
  ..............................................
  Cognitive, behavioral, and UCC
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
Cognitive-behavioral group therapy for irritable bowel syndrome: effects and long-term follow-up. van Dulmen et al, 1996 CCT | IBS More than 6 months | | | Measures: pain, GI symptoms, use of medication, psychological well-being score Overall, abdominal complaints improved significantly in those patients receiving treatment compared with control (UCC) group.
  % Female: | 51
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (waiting list)
  N entering: | 20
  N completing: | 18
  Setting: | Hospital
  ..............................................
  Behavioral, cognitive, and UCC
  N entering: | 27
  N completing: | 27
  Setting: | Hospital
The effects of a cognitive experiential therapy utilizing hypnosis, cognitive restructuring, and developmental staging on psychological factors associated with duodenal ulcer disease: a multivariate experimental study. Tosi et al, 1989 RCT | Peptic ulcer disease 6 months or less | | | Measures: psychological outcomes, self-reports of GI disturbances Overall, groups receiving cognitive restructuring and hypnosis differed significantly from all other arms with regard to the locus of control psychological measure.
  % Female: | 40
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 8
  N completing: | 8
  Setting: | Hospital
  ..............................................
  UCC (rational stage hypnotherapy)
  N entering: | 6
  N completing: | 6
  Setting: | Hospital
  ..............................................
  Cognitive and UCC
  N entering: | 6
  N completing: | 6
  Setting: | Hospital
  ..............................................
  Hypnosis and UCC
  N entering: | 5
  N completing: | 5
  Setting: | Hospital
Guided imagery - a significant advance in the care of patients undergoing elective colorectal surgery. Tusek et al, 1997 RCT | Colorectal surgery 6 months or less | | | Measures: pain, anxiety, narcotic consumption, time to first bowel movement, length of stay, number of complications Overall, compared to control group, total analgesic requirements, and pain scores were significantly lower in guided imagery group, as well as time to first bowel movement was significantly less.
  % Female: | Not reported
  % under 18: | Not reported
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC
  N entering: | 65
  N completing: | 65
  Setting: | Hospital
  ..............................................
  Imagery/visualization and UCC
  N entering: | 65
  N completing: | 63
  Setting: | Hospital
The influence of guided imagery on chemotherapy-related nausea and vomiting. Troesch et al, 1993 RCT | Nausea and Vomiting 6 months or less | | | Measures: nausea, vomiting, associated distress Overall, no significant difference between groups in patient perception of nausea, vomiting and distress. There was a significant improvement in the patient perception of the chemotherapy experience in the guided imagery group.
  % Female: | Not reported
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Yes
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC
  N entering: | 15
  N completing: | 14
  Setting: | Hospital
  ..............................................
  Imagery/visualization
  N entering: | 15
  N completing: | 14
  Setting: | Hospital
Placebo effect - is it important in diverticular-disease. Hodgson 1977 CCT | Diverticular disease More than 6 months | | | Measures: symptoms, pain, disturbance of bowel habit Overall, significant improvement in medication group, not in the placebo (sham) group.
  % Female: | 60
  % under 18: | 0
  % over 65: | Not reported
  Total Jadad score: | 3
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Yes
  Blinding appropriate: | Yes
  Withdrawals/dropouts described: | Yes
  Sham treatment
  N entering: | 13
  N completing: | 11
  Setting: | Hospital
  ..............................................
  Medication
  N entering: | 17
  N completing: | 16
  Setting: | Hospital
Components analyses of behavioral treatment of children diagnosed with recurrent abdominal pain. Humphreys, 1998 RCT | Abdominal pain 6 months or less | | | Measures: pain, symptoms, utilization of medical services, medication use, school attendance. Overall, 96% patients in the three active treatment groups had reduced levels of pain; 72% had complete elimination of symptoms.
  % Female: | 63
  % under 18: | 100
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (fiber)
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Biofeedback and UCC (fiber)
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
  ..............................................
  Biofeedback, cognitive, and UCC (fiber)
  N entering: | 16
  N completing: | 16
  Setting: | Hospital
  ..............................................
  Behavioral, biofeedback, cognitive, and UCC (parental support, fiber)
  N entering: | 15
  N completing: | 15
  Setting: | Hospital
Two controlled evaluations of multicomponent psychological treatment of irritable bowel syndrome. Blanchard et al, 1992 RCT | IBS 6 months or less | | | Measures: GI symptoms, avoidance activity, medication use, psychological tests Overall, multicomponent group did not differ significantly from the attention placebo group in any measure.
  % Female: | 76
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 1
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  UCC (symptom monitoring)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  UCC (attention placebo)
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
  ..............................................
  Biofeedback, cognitive, relaxation, and UCC
  N entering: | 10
  N completing: | 10
  Setting: | Hospital
Two controlled evaluations of multicomponent psychological treatment of irritable bowel syndrome. Blanchard et al, 1992 RCT | IBS More than 6 months | | | Measures: GI symptoms, avoidance activity, medication use, psychological tests Overall, all groups had significant reduction in GI symptoms, anxiety, and depression.
  % Female: | 56
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 2
  Randomized: | Yes
  Randomization appropriate: | Not described
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  UCC (symptom monitoring)
  N entering: | 31
  N completing: | 31
  Setting: | Hospital
  ..............................................
  UCC (attention placebo)
  N entering: | 30
  N completing: | 30
  Setting: | Hospital
  ..............................................
  Biofeedback, cognitive, relaxation, and UCC
  N entering: | 30
  N completing: | 30
  Setting: | Hospital
Behavioural techniques in the management of aerophagia in patients with hiatus hernia. Calloway et. al, 1983 CCT | Hiatus hernia More than 6 months | | | Measures: swallowing rate, skin conductance, symptoms Overall, swallowing rate of patients decreased in both groups.
  % Female: | 58
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 0
  Randomized: | No
  Randomization appropriate: | Not applicable
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | No
  Behavioral and UCC
  N entering: | 6
  N completing: | 6
  Setting: | Hospital
  ..............................................
  Behavioral and UCC
  N entering: | 6
  N completing: | 6
  Setting: | Hospital
A comparison of cognitive stress management, progressive muscle relaxation, and biofeedback in the treatment of irritable bowel syndrome. Bergeron, 1983 RCT | Inflammatory bowel disease 6 months or less | | | Measures: pain, bowel function, GI symptoms, IBS rating, psychological measures for anxiety and locus of control Overall, all three treatments caused decrease in physical IBS symptoms, but only relaxation and biofeedback caused decrease in psychological symptoms
  % Female: | 72
  % under 18: | 0
  % over 65: | 0
  Total Jadad score: | 3
  Randomized: | Yes
  Randomization appropriate: | Yes
  Double-blind: | Not described
  Blinding appropriate: | Not described
  Withdrawals/dropouts described: | Yes
  Behavioral and Cognitive
  N entering: | 12
  N completing: | 12
  Setting: | Hospital
  ..............................................
  Relaxation
  N entering: | 17
  N completing: | 13
  Setting: | Hospital
  ..............................................
  Biofeedback
  N entering: | 13
  N completing: | 12
  Setting: | Hospital

RCT = randomized controlled trial

BF = biofeedback

UCC = usual customary care

CCT = clinical controlled trial

GI = gastrointestinal

IBS = irritable bowel syndrome