# References

Achterberg J, Dossey L, Gordon JS, et al. Mind-Body Interventions. In: Alternative Medicine: Expanding Medical Horizons. A Report to the National Institutes of Health on Alternative Medical Systems and Practices in the United States, prepared under the auspices of the Workshop on Alternative Medicine, Chantilly, Virginia, September 14-16, 1992. Chantilly, Virginia: NIH Publication # 94-066; 1992.
Anton PA, Schoen M, Mayer E, et al Hypnosis not directed at specific symptoms fails to improve irritable bowel symptoms Gastroenterology 1997 Apr 112(N4):
Arawaka S. Effectiveness of progressive muscle relaxation in reducing nausea, vomiting and anxiety induced by chemotherapy in Japanese patients [dissertation]. Washington, DC: The Catholic University of America; 1995.
Astin JA, Shapiro SL, Schwartz GER. Meditation. In: Novey DW, editor. Clinician's Complete Reference to Complementary and Alternative Medicine. St. Louis: Mosby; 2000. pp.73-85.
Baime MJ. Meditation and mindfulness. In: Jonas WB and Levin JS, editors. Essentials of Complementary and Alternative Medicine. Baltimore, Lippincott Williams & Wilkins; 1999. pp. 522-336.
Beck R, Fernandez E Cognitive-behavioral therapy in the treatment of anger: a meta-analysis Cognitive Therapy and Research 1998 22(1):63 74
Benninga MA, van der Plas RN, Taminiau JA, et al Biofeedback training for children with recurrent abdominal-pain Gastroenterology 1996 Apr 110(N4):
Benson H, Beary J, et al. The relaxation response. Psychiatry. 1974;37:37-46. [pmid: 4810622].
Benson H Hypnosis and the relaxation response Gastroenterology 1989 96(6):1609 1611 2653945
Bergeron CM. A comparison of cognitive stress management, progressive muscle relaxation, and biofeedback in the treatment of irritable bowel syndrome [dissertation]. Colombia (MO): University of Missouri-Colombia; 1983.
Blanchard EB, Greene B, Scharff L, et al Relaxation training as a treatment for irritable bowel syndrome Biofeedback and Self Regul 1993 Sept 18(3):125 132
Blanchard EB, Schwarz SP, Suls JM, et al Two controlled evaluations of multicomponent psychological treatment of irritable bowel syndrome Behav Res Ther 1992 Mar 30(2):175 189 1567347
Bleijenberg G, Kuijpers HC Biofeedback treatment of constipation: a comparison of two methods Am J Gastroenterol 1994 July 89(7):1021 1026 8017359
Bowers TG, Clum GA Relative contribution of specific and nonspecific treatment effects: meta-analysis of placebo-controlled behavior therapy research Psychol Bull 1988 103(3):315 323 3289070
Bushman BJ. Vote-counting procedures in meta-analysis. In: Cooper H and Hedges LV, editors. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994.
Calloway SP, Fonagy P, Pounder RE, et al Behavioural techniques in the management of aerophagia in patients with hiatus hernia J Psychosom Res 1983 27(6):499 502 6363680
Caudill M, Schnable R, Zuttermeister P, et al. Decreased clinic utilization by chronic pain patients: Response to behavioral medicine intervention. Clin J Pain. 1991;7:305-310. [pmid: 1809444].
Chiaramonte DR Mind-body therapy for primary care physicians Primary Care 1997 24(4):787 805 9386256
Cohen J. Statistical Power Analysis for the Behavioral Sciences. (Rev. ed.). Hillsdale, NJ: Lawrence Erlbaum Associates; 1987.
Colgan SM, Faragher EB, Whorwell PJ Controlled trial of hypnotherapy in relapse prevention of duodenal ulceration Lancet 1988 June 1(8598):1299 1300 2897556
Cox DJ, Sutphen J, Borowitz S, et al Contribution of behavior therapy and biofeedback to laxative therapy in the treatment of pediatric encopresis Ann Behav Med 1998 20(2):70 6 9989311
Edwards MC, Finney JW, Bonner M Matching treatment with recurrent abdominal pain symptoms: an evaluation of dietary fiber and relaxation treatments Behavior Therapy 1991 22(2):257 267
Fernandez C, Perez M, Amigo I, et al Stress and contingency management in the treatment of irritable bowel syndrome Stress Medicine 1998 14(1):31 42
Forbes A, Macauley S, Chiotakakou-Faliakou E Hypnotherapy for irritable bowel syndrome (IBS) - a blinded randomised controlled trial Gut 1999 Apr 44(1):
Fynes MM, Marshall K, Cassidy M, et al A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma Dis Colon Rectum 1999 June 42(6):753 761 10378599
Galovski TE, Blanchard EB The treatment of irritable bowel syndrome with hypnotherapy Applied Psychophysiology Biofeedback 1998 23(4):219 232
Garcia-Alonso F, Guallar E, Bakke OM, et al. Use and abuse of placebo in phase III trials. Eur J Clin Pharmacol. 1998;54:101-105. [pmid: 9626912].
Garrick TR, Loewenstein RJ Behavioral medicine in the general hospital Behav Med 1989 30(2):123 134
Giles SL. Separate and combined effects of biofeedback training and brief individual psychotherapy in the treatment of gastrointestinal disorders [dissertation]. Boulder (CO): University of Colorado; 1978.
Glia A, Gylin M, Gullberg K, et al Biofeedback retraining in patients with functional constipation and paradoxical puborectalis contraction: comparison of anal manometry and sphincter electromyography for feedback Dis Colon Rectum 1997 Aug 40(8):889 895 9269803
Goleman D, Gurin J, editors. Mind Body Medicine. How to Use Your Mind for Better Health. Yonkers (NY): Consumer Reports Books;1993.
Green JA, Shellenberger R. Biofeedback therapy. In: Jonas WB, Levin JS, editors. Essentials of Complementary and Alternative Medicine. Baltimore: Lippincott Williams & Wilkins;1999; pp. 410-425.
Greene B, Blanchard EB Cognitive therapy for irritable bowel syndrome J Consult Clin Psychol 1994 62(3):576 582 8063984
Greer S. Psychological response to cancer and survival. Psychol Med. 1991;21:43-49. [pmid: 2047504].
Guillemot F, Bouche B, Gower-Rousseau C, et al Biofeedback for the treatment of fecal incontinence. Long-term clinical results Dis Colon Rectum 1994 Apr 38(4):393 397
Hawkins PJ, Liossi C, Ewart BW, et al. Hypnotherapy for control of anticipatory nausea and vomiting in children with cancer - preliminary findings. Psychooncology. 1995;4:101-106.
Heap M The nature of hypnosis Eur J Gastroenterol Hepatol 1996 8(6):515 519 8823560
Hedges LV, Olkin I. Vote-counting methods in research synthesis. Psychol Bull. 1980;88:359-369.
Hentschel C, Bauer J, Loew T, et al. A physical relaxation technique reduces psychological stress and improves quality-of-life in patients with irritable-bowel-syndrome. Gastroenterology. 1994;106.
Heymen S, Wexner SD, Vickers D, et al Prospective, randomized trial comparing four biofeedback techniques for patients with constipation Dis Colon Rectum 1999 42(11):1388 1393 10566525
Hodgson WJB Placebo effect - is it important in diverticular-disease Am J Gastroenterol 1977 67(N2):157 162 324270
Holli K Ineffectiveness of relaxation on vomiting induced by cancer chemotherapy Eur J Cancer 1993 29(13):1915 1916 8260255
Humphreys PA. Components analyses of behavioral treatment of children diagnosed with recurrent abdominal pain [dissertation]. San Diego (CA): California School of Professional Psychology; 1998.
Jadad AR, Moor AR, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Kabat-Zinn J. Mindfulness meditation. In: Haruki Y, Ishii Y, et al., editors. Comparative and Psychological Study on Meditation. The Netherlands: Eburon, 1996:161-170.
Kabat-Zinn J. Mindfulness meditation: health benefits of ancient Buddhist practice. In: Goleman D, Gurin J, editors. Mind Body Medicine. How to Use Your Mind for Better Health. Yonkers (NY): Consumer Reports Books;1993. pp.262-263.
Kabat-Zinn J, Lipworth L, Burney R. The clinical use of mindfulness meditation for the self-regulation of chronic pain. J Behav Med. 1985;8:163-190. [pmid: 3897551].
Kabat-Zinn J, Massion AO, Kristeller J, et al Effectiveness of meditation based stress reduction program in the treatment of anxiety disorders Am J Psychiatry 1992 149(7):936 943 1609875
Koutsomanis D, Lennard-Jones JE, Roy AJ, et al Controlled randomised trial of visual biofeedback versus muscle training without a visual display for intractable constipation Gut 1995 July 37(1):95 99 7672690 1382776
Lazar JS Mind-body medicine in primary care Prim Care 1996 23(1):169 181 8900514
Leroi AM, Duval V, Roussignol C, et al Biofeedback for anismus in 15 sexually abused women Int J Colorectal Dis 1996 11(4):187 190 8876277
Levy S, Herberman R, Lippman M, et al. Correlation of stress factors with sustained depression of natural killer cell activity and predicted prognosis in patients with breast cancer. J Clin Oncol. 1987;5:348-353. [pmid: 3546612].
Lipsey MW, Wilson DB. The efficacy of psychological, educational, and behavioral treatment. Confirmation from meta-analysis. Am Psychol. 1993 Dec:1181-1209.
Loening-Baucke V Biofeedback treatment for chronic constipation and encopresis in childhood: long-term outcome Pediatrics 1995 Jul 96(1):105 110 7596696
Loening-Baucke V Does biofeedback treatment of anismus improve longterm outcome in constipation? Neurogastroenterology Mot 1994 Jun 6(2):
Logue P, Edwards CL Fact or fiction for treating pain and related disorders? NCMJ 1998 59(3):176 179 9610160
Lynch, PM, Zamble E. A controlled behavioral treatment study of irritable bowel syndrome. Behavior Therapy. 1989;20:509-523.
McDowell BJ, Engberg S., Sereika S., et al Effectiveness of behavioral therapy to treat incontinence in homebound older adults J Am Geriatr Soc 1999 Mar 47(3):309 318 10078893
McHugh S, Walma K, Diamant NE Fecal incontinence - a controlled trial of biofeedback Gastroenterology 1986 90(N5):
Meersin FZ. Stress-induced arrhythmic disease of the heart-Part 1. Clin Cardiology. 1994;17:362-371.
Meyer J. Systematic desensitization versus relaxation training and no treatment (controls) for the reduction of nausea, vomiting and anxiety resulting from chemotherapy [dissertation]. Richmond (VA): Virginia Commonwealth University; 1983.
Miner PB, Donnelly TC, Read NW Investigation of mode of action of biofeedback in treatment of fecal incontinence Dig Dis Sci 1990 Oct 35(10):1291 1298 2209296
Moher D, Pham B, Jones A, et al. Does quality of reports of randomized trials affect the estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-613. [pmid: 9746022].
Morrow GR, Morrell C Behavioral treatment for the anticipatory nausea and vomiting induced by cancer chemotherapy N Engl J Med 1982 Dec 307(24):1476 1480 6128673
Nolan T, Catto-Smith T, Coffey C, et al Randomised controlled trial of biofeedback training in persistent encopresis with anismus Arch Dis Child 1998 Aug 79(2):131 135 9797593
Nolan T, Debelle G, Oberklaid F, et al Randomised trial of laxatives in treatment of childhood encopresis Lancet 1991 Aug 338(8766):523 527 1678797
Olson RP. Definitions of biofeedback and applied psychophysiology. In: Schwartz MS. Biofeedback. A Practitioners Guide. New York: Gulford Press; 1995. pp. 27-31.
Panconesi E, Gallassi F, Sarti MG, et al. Biofeedback, cognitive-behavioral methods, hypnosis: “alternative psychotherapy?”. Clin Dermatol. 1999;16:709-710.
Payne A, Blanchard EB. A controlled comparison of cognitive therapy and self-help support groups in the treatment of irritable-bowel-syndrome. J Consult Clin Psychol. 1995;63:779-786. [pmid: 7593870].
Rosenman RH, Friedman M, Straus, et al. A predictive study of coronary heart disease. JAMA. 1964;189:15-22. [pmid: 14149016].
Rossman ML, Bresler DE. Interactive guided imagery. In: Novey DW, editor. Clinician's Complete Reference to Complementary and Alternative Medicine. St. Louis: Mosby; 2000. pp. 64-72.
Saichek KI. Hypnotherapy. In: Novey DW, editor. Clinician's Complete Reference to Complementary and Alternative Medicine. St. Louis: Mosby; 2000. pp. 53-63.
Sanders MR, Rebgetz M, Morrison M, et al Cognitive-behavioral treatment of recurrent nonspecific abdominal pain in children: an analysis of generalization, maintenance, and side effects J Consult Clin Psychol 1989 57(2):294 300 2708618
Schmidt CF. Hypnotic suggestions and imaginations in the treatment of colitis ulcerosa. Hypnos. 1992:237-242.
Schrodt GR, Tasman A. Behavioral medicine. In: Jonas WB, Levin JS, editors. Essentials of Complementary and Alternative Medicine. Baltimore: Lippincott Williams & Wilkins; 1999. pp. 444-458.
Schwartz M, Schwartz N. Biofeedback: using the body's signals. In: Goleman D, Gurin J, editors. Mind Body Medicine. How to Use Your Mind for Better Health. Yonkers (NY): Consumer Reports Books, 1993.
Shaw G, Srivastava ED, Sadlier M, et al Stress management for irritable bowel syndrome: a controlled trial Digestion 1991 50(1):36 42 1804731
Shaw L, Ehrlich A Relaxation training as a treatment for chronic pain caused by ulcerative colitis Pain 1987 June 29(3):287 293 3302842
Sobel DS, Ornstein R. The Healthy Mind and Healthy Body Handbook. New York: Patient Education Media; 1996.
Spanos NP, Snyder CR, Donelson R, editors. Hypnosis, hypnotizability, and hypnotherapy. Handbook of Social and Clinical Psychology. 1991:644-663.
Stamatiadis A, Polimeneas G Biofeedback therapy of functional anorectal disorders Hellenic J Gastroenterology 1997 10(1):29 32
Stuart EM, Caudill M, Lesserman J, et al. Nonpharmacologic treatment of hypertension: a multiple risk-factor approach. Journal of Cardiovascular Nursing. 1987;1:1-14.
Tosi DJ, Judah SM, Murphy MA The effects of a cognitive experiential therapy utilizing hypnosis, cognitive restructuring, and developmental staging on psychological factors associated with duodenal ulcer disease: a multivariate experimental study Journal of Cognitive Psychotherapy 1989 3(4):273 290
Troesch LM, Rodehaver CB, Delaney EA, et al The influence of guided imagery on chemotherapy-related nausea and vomiting Oncol Nurs Forum 1993 Sept 20(8):1179 1185 8415147
Tusek D, Church JM, Strong SA, et al Guided imagery - a significant advance in the care of patients undergoing elective colorectal surgery Dis Colon Rectum 1997 Feb 40(N2):172 178 9075752
van der Plas RN, Benninga MA, Buller HA, et al Biofeedback training in treatment of childhood constipation: a randomised controlled study Lancet 1996 348(9030):776 780 8813983
van der Plas RN, Benninga MA, Redekop WK, et al Randomised trial of biofeedback training for encopresis Arch Dis Child 1996 Nov 75(5):367 374 8957948
van Dulmen AM, Fennis JFM, Bleijenberg G Cognitive-behavioral group therapy for irritable bowel syndrome: effects and long-term follow-up Psychosom Med 1996 58(5):508 514 8902902
Vickers A, Zollman C. Hypnosis and relaxation therapies. BMJ. 1999;319:1346-1349. [pmid: 10567143]. [pmcid: 1117083].
Wald A, Chandra R, Gabel S, et al Evaluation of biofeedback in childhood encopresis J Pediatr Gastroenterol Nutr 1987 6(4):554 558 3430263
Wald A Biofeedback therapy for fecal incontinence Ann Intern Med 1981 95(2):146 149 7258862
Welgan P, Bondi M, Hoehler F A comparison of biofeedback and stress management in the control of irritable bowel syndrome Gastroenterology 1986 90(N5):
Whitehead WE, Schuster MM. Gastrointestinal Disorders; Behavioral and Physiological Basis for Treatment. Orlando: Academic Press, Inc.; 1985.
Whitehead WE Behavioral medicine approaches to gastrointestinal disorders J Consult Clin Psychol 1992 60(4):605 612 1506508
Whorwell PJ, Prior A, Faragher EB. Hypnotherapy in severe refractory irritable bowel syndrome. Lancet. 1984;ii:1232-1233.
Wickramasekera I. Hypnotherapy. In: Jonas WB, Levin JS, editors. Essentials of Complementary and Alternative Medicine. Baltimore: Lippincott Williams & Wilkins; 1999. pp. 426-443.
Williams R, Haney T, Lee K, et al. Type A behavior, hostility, and coronary atherosclerosis. Psychosom Med. 1980;42:539-549. [pmid: 7465739].
Wolpe J. Psychotherapy by Reciprocal Inhibition. Stanford (CA): Stanford University Press; 1958.
Zeltzer L, LeBaron S, Zeltzer PM The effectiveness of behavioral intervention for reduction of nausea and vomiting in children and adolescents receiving chemotherapy J Clin Oncol 1984 June 2(6):683 690 6726307
Zeltzer LK, LeBaron S, et al A randomized, controlled-study of hypnotic and nonhypnotic behavioral intervention for chemotherapy-related nausea and vomiting Pediatric Res 1987 21(4;part 2):