# Appendix C: Long Screening Form

Article ID:________________ | Reviewer:________________
First Author:______________________________________
(Last Name Only)
Study Number:_____of_____ | Date of Publication:________________
(Enter ‘1of 1’ if only one)
Description (if more than one study):________________________

Study Quality
1. | Design: | | (circle one)
1. | Meta-analysis/systematic review........................................... | | 1
1. | Descriptive (editorial)............................................................... | | 2
1. | RCT............................................................................................. | | 3
1. | CCT............................................................................................. | | 4
1. | CBA............................................................................................ | | 5
1. | Interrupted time series............................................................. | | 6
1. | Simple Pre and Post.................................................................. | | 7
1. | Cohort......................................................................................... | | 8
1. | Case Series................................................................................. | | 9
1. | Case Study............................................................................... | | 10
1. | >Case Control............................................................................ | | 11
1. | Other (specify:___________________)... | | 12
1. | Not described.......................................................................... | | 98
1. | If RCT or CCT, then answer #2-6; otherwise skip to #7.
2. | Is the study described as randomized? | | (circle one)
2. | Yes.............................................................................................. | | 1
2. | No................................................................................................ | | 2
3. | If the study was randomized, was method of randomization appropriate? | | (circle one)
3. | Yes.............................................................................................. | | 1
3. | No................................................................................................ | | 2
3. | Method not described............................................................. | | 8
3. | Not applicable (study not randomized)................................. | | 9
4. | Is the study described as: | | (circle one)
4. | Double blind.............................................................................. | | 1
4. | Single blind, patient.................................................................. | | 2
4. | Single blind, outcome assessment........................................ | | 3
4. | Open........................................................................................... | | 4
4. | Blinding not described............................................................. | | 8
5. | If reported, was the method of double blinding appropriate? | | (circle one)
5. | Yes.............................................................................................. | | 1
5. | No................................................................................................ | | 2
5. | Double blinding not described............................................... | | 8
5. | Not applicable (not double blinded)...................................... | | 9
6. | If study was randomized, did the method of randomization provide for concealment of allocation? | | (circle one)
6. | Yes.............................................................................................. | | 1
6. | No................................................................................................ | | 2
6. | Concealment not described..................................................... | | 8
6. | Not applicable (not randomized)............................................ | | 9
7. | If case control design, was there blinded assessment of eligibility of cases and controls? | | (circle one)
7. | Yes.............................................................................................. | | 1
7. | No................................................................................................ | | 2
7. | Blinding to eligibility not described....................................... | | 8
7. | Not a case control study......................................................... | | 9
8. | If case control design, was there blinded assessment of exposure? | | (circle one)
8. | Yes.............................................................................................. | | 1
8. | No................................................................................................ | | 2
8. | Blinding to exposure not described....................................... | | 8
8. | Not a case control study......................................................... | | 9
9. | If cohort design, was there blinded assessment of outcomes? | | (circle one)
9. | Yes.............................................................................................. | | 1
9. | No................................................................................................ | | 2
9. | Blinding to outcomes not described...................................... | | 8
9. | Not a cohort study................................................................... | | 9
10. | Is there a description of withdrawals and dropouts? | | (circle one)
10. | Yes.............................................................................................. | | 1
10. | No................................................................................................ | | 2
11. | Are reasons for withdrawal given? | | (circle one)
11. | Yes.............................................................................................. | | 1
11. | No................................................................................................ | | 2
11. | Not applicable (no withdrawals)............................................. | | 9
12. | Is this a cross-over study design? | | (circle one)
12. | Yes.............................................................................................. | | 1
12. | No................................................................................................ | | 2
12. | Not applicable (not a controlled study)................................ | | 9
Patient Characteristics
13. | Type of disease (check all that apply):
13. | Abdominal pain........................ | [image] | GERD....................................... | [image]
13. | Bacterial overgrowth syndrome | [image] | Hepatitis................................... | [image]
13. | Celiac sprue.............................. | [image] | Inflamatory bowel disease........ | [image]
13. | Cholecystitis/gallstone disease. | [image] | Ileus.......................................... | [image]
13. | Colon cancer............................. | [image] | Irritable bowel syndrome.......... | [image]
13. | Constipation............................. | [image] | Maldigestion............................. | [image]
13. | Crohns disease.......................... | [image] | Malabsorption.......................... | [image]
13. | Diarrhea.................................... | [image] | Nausea...................................... | [image]
13. | Diverticular disease................... | [image] | Peptic ulcer disease................... | [image]
13. | Fecal incontinence/encopresis... | [image] | Small bowel obstruction........... | [image]
13. | Gastric carcinoma..................... | [image] | Ulcerative colitis....................... | [image]
13. | Gastritis.................................... | [image] | Vomiting................................... | [image]
13. | Disease non-specific................................................................................... | | | [image]
13. | Other (specify:___________________).......... | | | [image]
14. | Are the eligibility criteria described? | | (circle one)
14. | Yes.............................................................................................. | | 1
14. | No................................................................................................ | | 2
15. | Are inclusion/exclusion criteria described? | | (circle one)
15. | Yes.............................................................................................. | | 1
15. | No................................................................................................ | | 2
16. | Is the gender of participants reported? | | (circle one)
16. | Yes.............................................................................................. | | 1
16. | No................................................................................................ | | 2
17. | Is the age of participants reported? | | (circle one)
17. | Yes.............................................................................................. | | 1
17. | No................................................................................................ | | 2
18. | Is the race/ethnicity of participants described? | | (circle one)
18. | Yes.............................................................................................. | | 1
18. | No................................................................................................ | | 2
19. | Is the SES of participants described? | | (circle one)
19. | Yes.............................................................................................. | | 1
19. | No................................................................................................ | | 2
20. | From where were study participants recruited? | | (check all that apply)
20. | Self-referral.............................................................................. | | [image]
20. | Western/mainstream practice............................................... | | [image]
20. | CAM practice......................................................................... | | [image]
20. | Source not described............................................................. | | [image]
21. | Is there a measure of disease severity? | | (circle one)
21. | Yes.............................................................................................. | | 1
21. | No................................................................................................ | | 2
22. | Is the duration of disease described? | | (circle one)
22. | Yes.............................................................................................. | | 1
22. | No................................................................................................ | | 2
23. | Are comorbidities described? | | (circle one)
23. | Yes.............................................................................................. | | 1
23. | No................................................................................................ | | 2
24. | Are any prognostic indicators given? | | (circle one)
24. | Yes.............................................................................................. | | 1
24. | No................................................................................................ | | 2
25. | Were the groups comparable before the intervention with regard to demographics? | | (circle one)
25. | Yes.............................................................................................. | | 1
25. | No................................................................................................ | | 2
25. | Demographics not described.................................................. | | 8
25. | Not applicable (only one group)............................................ | | 9
26. | Were the groups comparable before the intervention with regard to diagnosis? | | (circle one)
26. | Yes.............................................................................................. | | 1
26. | No................................................................................................ | | 2
26. | Diagnosis not described.......................................................... | | 8
26. | Not applicable (only one group)............................................ | | 9
27. | Were the groups comparable before the intervention with regard to prognosis? | | (circle one)
27. | Yes.............................................................................................. | | 1
27. | No................................................................................................ | | 2
27. | Prognosis not described.......................................................... | | 8
27. | Not applicable (only one group)............................................ | | 9

If study has a control group, then enter data for that group here. Otherwise, enter data for each group in order of first mention.
Arm 1 of | ____ | Description: | ___________________________

28. | Intervention modality(check all that apply) :
28. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
28. | Biofeedback................... | [image] | Hypnosis........................ | [image]
28. | Cognitive........................ | [image] | Meditation...................... | [image]
28.
28. | Placebo........................... | [image] | Yoga................................ | [image]
28. | Relaxation....................... | [image] | Usual customary care:.. | [image]
28. | Sham treatment..............
28.
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________) | | | [image]
29. | What was the sample size in this intervention arm?
29. | ___ ___ ___,___ ___ ___ | | ___ ___ ___, ___ ___ ___
29. | Entering | | Completing
29. | (Enter 999,999 if not reported.)
30. | Setting of the intervention(s): | | (check all that apply)
30. | Community.............................................................................. | | [image]
30. | Private clinic............................................................................ | | [image]
30. | Hospital................................................................................... | | [image]
30. | CAM Practice......................................................................... | | [image]
30. | Other (specify:___________________) | | [image]
30. | Not described......................................................................... | | [image]
31. | Was there a protocol for the intervention? | | (circle one)
31. | Yes.............................................................................................. | | 1
31. | No................................................................................................ | | 2
31. | Not reported.............................................................................. | | 8
32. | Is the frequency of the intervention described? | | (circle one)
32. | Yes.............................................................................................. | | 1
32. | No................................................................................................ | | 2
33. | Is the duration of the intervention described? | | (circle one)
33. | Yes.............................................................................................. | | 1
33. | No................................................................................................ | | 2
34. | Is the intensity of the intervention described? | | (circle one)
34. | Yes.............................................................................................. | | 1
34. | No................................................................................................ | | 2
35. | Are contraindications for the therapy described? | | (circle one)
35. | Yes.............................................................................................. | | 1
35. | No................................................................................................ | | 2
36. | Were the therapist(s) qualifications appropriate? | | (circle one)
36. | Yes.............................................................................................. | | 1
36. | No................................................................................................ | | 2
36. | Qualifications not described................................................... | | 8
37. | Were the therapists homogeneous? | | (circle one)
37. | Yes.............................................................................................. | | 1
37. | No................................................................................................ | | 2
37. | Therapists not described......................................................... | | 8
38. | If described, did the co-interventions include(check all that apply) :
38. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
38. | Biofeedback................... | [image] | Hypnosis........................ | [image]
38. | Cognitive........................ | [image] | Meditation...................... | [image]
38.
38. | Placebo........................... | [image] | Yoga................................ | [image]
38. | Relaxation....................... | [image] | Medication:.................... | [image]
38. | Sham treatment.............. | [image]
38.
38. | Other (specify:___________________) | | | [image]
38. | Other (specify:___________________) | | | [image]
38. | Not applicable (co-interventions not described)............ | | | [image]

Enter data for each group in order of first mention.
Arm 2 of | ____ | Description: | ___________________________

28. | Intervention modality(check all that apply) :
28. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
28. | Biofeedback................... | [image] | Hypnosis........................ | [image]
28. | Cognitive........................ | [image] | Meditation...................... | [image]
28.
28. | Placebo........................... | [image] | Yoga................................ | [image]
28. | Relaxation....................... | [image] | Usual customary care:.. | [image]
28. | Sham treatment..............
28.
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________) | | | [image]
29. | What was the sample size in this intervention arm?
29. | ___ ___ ___, ___ ___ ___ | | ___ ___ ___, ___ ___ ___
29. | Entering | | Completing
29. | (Enter 999,999 if not reported.)
30. | Setting of the intervention(s): | | (check all that apply)
30. | Community.............................................................................. | | [image]
30. | Private clinic............................................................................ | | [image]
30. | Hospital................................................................................... | | [image]
30. | CAM Practice......................................................................... | | [image]
30. | Other (specify:___________________) | | [image]
30. | Not described......................................................................... | | [image]
31. | Was there a protocol for the intervention? | | (circle one)
31. | Yes.............................................................................................. | | 1
31. | No................................................................................................ | | 2
31. | Not reported.............................................................................. | | 8
32. | Is the frequency of the intervention described? | | (circle one)
32. | Yes.............................................................................................. | | 1
32. | No................................................................................................ | | 2
33. | Is the duration of the intervention described? | | (circle one)
33. | Yes.............................................................................................. | | 1
33. | No................................................................................................ | | 2
34. | Is the intensity of the intervention described? | | (circle one)
34. | Yes.............................................................................................. | | 1
34. | No................................................................................................ | | 2
35. | Are contraindications for the therapy described? | | (circle one)
35. | Yes.............................................................................................. | | 1
35. | No................................................................................................ | | 2
36. | Were the therapist(s) qualifications appropriate? | | (circle one)
36. | Yes.............................................................................................. | | 1
36. | No................................................................................................ | | 2
36. | Qualifications not described................................................... | | 8
37. | Were the therapists homogeneous? | | (circle one)
37. | Yes.............................................................................................. | | 1
37. | No................................................................................................ | | 2
37. | Therapists not described......................................................... | | 8
38. | If described, did the co-interventions include(check all that apply) :
38. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
38. | Biofeedback................... | [image] | Hypnosis........................ | [image]
38. | Cognitive........................ | [image] | Meditation...................... | [image]
38.
38. | Placebo........................... | [image] | Yoga................................ | [image]
38. | Relaxation....................... | [image] | Medication:.................... | [image]
38. | Sham treatment.............. | [image]
38.
38. | Other (specify:___________________) | | | [image]
38. | Other (specify:___________________) | | | [image]
38. | Not applicable (co-interventions not described)............ | | | [image]

Enter data for each group in order of first mention.
Arm 3 of | ____ | Description: | ___________________________

28. | Intervention modality(check all that apply) :
28. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
28. | Biofeedback................... | [image] | Hypnosis........................ | [image]
28. | Cognitive........................ | [image] | Meditation...................... | [image]
28. | Placebo........................... | [image] | Yoga................................ | [image]
28. | Relaxation....................... | [image] | Usual customary care:.. | [image]
28. | Sham treatment..............
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________) | | | [image]
29. | What was the sample size in this intervention arm?
29. | ___ ___ ___, ___ ___ ___ | | ___ ___ ___, ___ ___ ___
29. | Entering | | Completing
29. | (Enter 999,999 if not reported.)
30. | Setting of the intervention(s): | | (check all that apply)
30. | Community.............................................................................. | | [image]
30. | Private clinic............................................................................ | | [image]
30. | Hospital................................................................................... | | [image]
30. | CAM Practice......................................................................... | | [image]
30. | Other (specify:___________________) | | [image]
30. | Not described......................................................................... | | [image]
31. | Was there a protocol for the intervention? | | (circle one)
31. | Yes.............................................................................................. | | 1
31. | No................................................................................................ | | 2
31. | Not reported.............................................................................. | | 8
32. | Is the frequency of the intervention described? | | (circle one)
32. | Yes.............................................................................................. | | 1
32. | No................................................................................................ | | 2
33. | Is the duration of the intervention described? | | (circle one)
33. | Yes.............................................................................................. | | 1
33. | No................................................................................................ | | 2
34. | Is the intensity of the intervention described? | | (circle one)
34. | Yes.............................................................................................. | | 1
34. | No................................................................................................ | | 2
35. | Are contraindications for the therapy described? | | (circle one)
35. | Yes.............................................................................................. | | 1
35. | No................................................................................................ | | 2
36. | Were the therapist(s) qualifications appropriate? | | (circle one)
36. | Yes.............................................................................................. | | 1
36. | No................................................................................................ | | 2
36. | Qualifications not described................................................... | | 8
37. | Were the therapists homogeneous? | | (circle one)
37. | Yes.............................................................................................. | | 1
37. | No................................................................................................ | | 2
37. | Therapists not described......................................................... | | 8
38. | If described, did the co-interventions include(check all that apply) :
38. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
38. | Biofeedback................... | [image] | Hypnosis........................ | [image]
38. | Cognitive........................ | [image] | Meditation...................... | [image]
38.
38. | Placebo........................... | [image] | Yoga................................ | [image]
38. | Relaxation....................... | [image] | Medication:.................... | [image]
38. | Sham treatment.............. | [image]
38. | Other (specify:___________________) | | | [image]
38. | Other (specify:___________________) | | | [image]
38. | Not applicable (co-interventions not described)............ | | | [image]

Enter data for each group in order of first mention.
Arm 4 of | ____ | Description: | ___________________________

28. | Intervention modality(check all that apply) :
28. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
28. | Biofeedback................... | [image] | Hypnosis........................ | [image]
28. | Cognitive........................ | [image] | Meditation...................... | [image]
28. | Placebo........................... | [image] | Yoga................................ | [image]
28. | Relaxation....................... | [image] | Usual customary care:.. | [image]
28. | Sham treatment..............
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________) | | | [image]
29. | What was the sample size in this intervention arm?
29. | ___ ___ ___, ___ ___ ___ | | ___ ___ ___, ___ ___ ___
29. | Entering | | Completing
29. | (Enter 999,999 if not reported.)
30. | Setting of the intervention(s): | | (check all that apply)
30. | Community.............................................................................. | | [image]
30. | Private clinic............................................................................ | | [image]
30. | Hospital................................................................................... | | [image]
30. | CAM Practice......................................................................... | | [image]
30. | Other (specify:___________________) | | [image]
30. | Not described......................................................................... | | [image]
31. | Was there a protocol for the intervention? | | (circle one)
31. | Yes.............................................................................................. | | 1
31. | No................................................................................................ | | 2
31. | Not reported.............................................................................. | | 8
32. | Is the frequency of the intervention described? | | (circle one)
32. | Yes.............................................................................................. | | 1
32. | No................................................................................................ | | 2
33. | Is the duration of the intervention described? | | (circle one)
33. | Yes.............................................................................................. | | 1
33. | No................................................................................................ | | 2
34. | Is the intensity of the intervention described? | | (circle one)
34. | Yes.............................................................................................. | | 1
34. | No................................................................................................ | | 2
35. | Are contraindications for the therapy described? | | (circle one)
35. | Yes.............................................................................................. | | 1
35. | No................................................................................................ | | 2
36. | Were the therapist(s) qualifications appropriate? | | (circle one)
36. | Yes.............................................................................................. | | 1
36. | No................................................................................................ | | 2
36. | Qualifications not described................................................... | | 8
37. | Were the therapists homogeneous? | | (circle one)
37. | Yes.............................................................................................. | | 1
37. | No................................................................................................ | | 2
37. | Therapists not described......................................................... | | 8
38. | If described, did the co-interventions include(check all that apply) :
38. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
38. | Biofeedback................... | [image] | Hypnosis........................ | [image]
38. | Cognitive........................ | [image] | Meditation...................... | [image]
38.
38. | Placebo........................... | [image] | Yoga................................ | [image]
38. | Relaxation....................... | [image] | Medication:.................... | [image]
38. | Sham treatment.............. | [image]
38. | Other (specify:___________________) | | | [image]
38. | Other (specify:___________________) | | | [image]
38. | Not applicable (co-interventions not described)............ | | | [image]

Enter data for each group in order of first mention.
Arm 5 of | ____ | Description: | ___________________________

28. | Intervention modality(check all that apply) :
28. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
28. | Biofeedback................... | [image] | Hypnosis........................ | [image]
28. | Cognitive........................ | [image] | Meditation...................... | [image]
28. | Placebo........................... | [image] | Yoga................................ | [image]
28. | Relaxation....................... | [image] | Usual customary care:.. | [image]
28. | Sham treatment..............
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________).... | | | [image]
28. | Other (specify:___________________) | | | [image]
29. | What was the sample size in this intervention arm?
29. | ___ ___ ___, ___ ___ ___ | | ___ ___ ___, ___ ___ ___
29. | Entering | | Completing
29. | (Enter 999,999 if not reported.)
30. | Setting of the intervention(s): | | (check all that apply)
30. | Community.............................................................................. | | [image]
30. | Private clinic............................................................................ | | [image]
30. | Hospital................................................................................... | | [image]
30. | CAM Practice......................................................................... | | [image]
30. | Other (specify:___________________) | | [image]
30. | Not described......................................................................... | | [image]
31. | Was there a protocol for the intervention? | | (circle one)
31. | Yes.............................................................................................. | | 1
31. | No................................................................................................ | | 2
31. | Not reported.............................................................................. | | 8
32. | Is the frequency of the intervention described? | | (circle one)
32. | Yes.............................................................................................. | | 1
32. | No................................................................................................ | | 2
33. | Is the duration of the intervention described? | | (circle one)
33. | Yes.............................................................................................. | | 1
33. | No................................................................................................ | | 2
34. | Is the intensity of the intervention described? | | (circle one)
34. | Yes.............................................................................................. | | 1
34. | No................................................................................................ | | 2
35. | Are contraindications for the therapy described? | | (circle one)
35. | Yes.............................................................................................. | | 1
35. | No................................................................................................ | | 2
36. | Were the therapist(s) qualifications appropriate? | | (circle one)
36. | Yes.............................................................................................. | | 1
36. | No................................................................................................ | | 2
36. | Qualifications not described................................................... | | 8
37. | Were the therapists homogeneous? | | (circle one)
37. | Yes.............................................................................................. | | 1
37. | No................................................................................................ | | 2
37. | Therapists not described......................................................... | | 8
38. | If described, did the co-interventions include(check all that apply) :
38. | Behavioral...................... | [image] | Imagery/visualization.... | [image]
38. | Biofeedback................... | [image] | Hypnosis........................ | [image]
38. | Cognitive........................ | [image] | Meditation...................... | [image]
38.
38. | Placebo........................... | [image] | Yoga................................ | [image]
38. | Relaxation....................... | [image] | Medication:.................... | [image]
38. | Sham treatment.............. | [image]
38. | Other (specify:___________________) | | | [image]
38. | Other (specify:___________________) | | | [image]
38. | Not applicable (co-interventions not described)............ | | | [image]

Outcomes
39. | Type of outcomes measured:
39. | (Check all that apply. Circle at least one of the letters “P”, “A”, and “L” for each outcome measured. If rating method is not described, circle ONLY “ND”.) | | Patient, assessor, or laboratory rated? (ND=not described)
39. | Pain............................................................ | [image] | P | A | | ND
39. | Days lost from work................................ | [image] | P | A | L | ND
39. | Physical functioning............................... | [image] | P | A | L | ND
39. | Physiological changes............................ | [image] | P | A | L | ND
39. | Decrease in pharmaceutical medications | [image] | P | A | L | ND
39. | Psychological........................................... | [image] | P | A | L | ND
39. | Quality of life............................................ | [image] | P | | | ND
39. | Mortality................................................... | [image] | | A | L | ND
39. | Change in symptoms.............................. | [image] | P | A | | ND
39. | Other (specify:___________________) | [image] | P | A | L | ND
39. | Other (specify:___________________) | [image] | P | A | L | ND
39. | Other (specify:___________________) | [image] | P | A | L | ND

Evaluation
40. | Was the outcome assessment comparable in each intervention arm? | | (circle one)
40. | Yes.............................................................................................. | | 1
40. | No................................................................................................ | | 2
40. | Outcome assessment not described...................................... | | 8
40. | Only one intervention arm....................................................... | | 9
41. | Which adverse effects were reported?
41. | | Reported & measured | Mentioned only | Not mentioned
41. | Mortality................................................ | [image] | [image] | [image]
41. | Hospitalization...................................... | [image] | [image] | [image]
41. | Worsening of underlying condition.. | [image] | [image] | [image]
41. | Psychological trauma........................... | [image] | [image] | [image]
41. | Other complications............................. | [image] | [image] | [image]
41. | Other (specify:___________________). | [image] | [image] | [image]
41. | None described.......................................................................... | | | [image]
42. | Which follow-up measures are reported? | | (check all that apply)
42. | Short-term (6 months or less)............................................... | | [image]
42. | Long-term (More than 6 months)........................................ | | [image]
42. | Timing not reported............................................................... | | [image]
43.
43. | Are the validity and/or reliability of outcome measures known or described? | | (circle one)
43. | Yes.............................................................................................. | | 1
No................................................................................................ | | 2
44. | If new scales were used, were they pretested? | | (circle one)
44. | Yes.............................................................................................. | | 1
44. | No................................................................................................ | | 2
44. | Testing not described.............................................................. | | 8
44. | Not applicable (New scales not used)................................... | | 9
45. | What was the principle focus of the study? | | (circle one)
45. | Efficacy....................................................................................... | | 1
45. | Effectiveness............................................................................. | | 2
45. | Toxicity....................................................................................... | | 3
45. | Other (specify:___________________)................... | | 4
46. | If the study was randomized, what was the unit of randomization? | | (circle one)
46. | Patient......................................................................................... | | 1
46. | Family......................................................................................... | | 2
46. | Provider...................................................................................... | | 3
46. | Organization (practice, hospital, HMO)................................ | | 4
46. | Community................................................................................. | | 5
46. | Other (specify:___________________)................... | | 6
46. | Not reported.............................................................................. | | 8
46. | Not a randomized study........................................................... | | 9
47. | What was the unit of analysis? | | (circle one)
47. | Patient......................................................................................... | | 1
47. | Family......................................................................................... | | 2
47. | Provider...................................................................................... | | 3
47. | Organization (practice, hospital, HMO)................................ | | 4
47. | Community................................................................................. | | 5
47. | Other (specify:___________________)................... | | 6
47. | Not reported.............................................................................. | | 8
48. | Did the analysis include intention-to-treat analysis? | | (circle one)
48. | Yes.............................................................................................. | | 1
48. | No................................................................................................ | | 2
49. | Are the frequencies of outcomes reported for each arm? | | (circle one)
49. | Yes.............................................................................................. | | 1
49. | No................................................................................................ | | 2
50. | Are point estimates for outcomes reported for each arm (e.g., means, medians, modes)? | | (circle one)
50. | Yes.............................................................................................. | | 1
50. | No................................................................................................ | | 2
51. | Are measures of variability reported for each arm (e.g., standard deviation, interquartile range, confidence interval)? | | (circle one)
51. | Yes.............................................................................................. | | 1
51. | No................................................................................................ | | 2
52. | Are odds ratios reported? | | (circle one)
52. | Yes.............................................................................................. | | 1
52. | No................................................................................................ | | 2
53. | Are P-values reported? | | (circle one)
53. | Yes.............................................................................................. | | 1
53. | No................................................................................................ | | 2
54. | If none of the above were collected, are other quantitative results reported? | | (circle one)
54. | Yes.............................................................................................. | | 1
54. | No................................................................................................ | | 2
55. | What was the percent of female participants?
55. | ___ ___ ___%
55. | (Enter 999 if not reported)
56. | What was the percent of participants less than 18 years of age?
56. | ___ ___ ___ %
56. | (Enter 999 if not reported)
57. | What was the percent of participants over 65 years of age?
57. | ___ ___ ___ %
57. | (Enter 999 if not reported)
58. | Are refusal rates reported? | | (circle one)
58. | Yes.............................................................................................. | | 1
58. | No................................................................................................ | | 2
59. | Are compliance rates acceptable? | | (circle one)
59. | Yes.............................................................................................. | | 1
59. | No................................................................................................ | | 2
59. | Not reported.............................................................................. | | 9