# Appendix B: Short Screening Form

00000 | MIND & BODY TITLE Screener | RAND EPC Alternative Medicine | Reviewers: | Assigned on:
Article title

1. | Data Source: | Circle One
1. | Title................................................................... | 1
1. | Abstract........................................................... | 2
1. | Article............................................................... | 3
1. | Other (Specify:___________________).......... | 4
2. | Subject of Article: | Circle One
2. | Mind-Body...................................................... | 1
2. | Ayurveda Only............................................... | 2 | (STOP)
2. | Neither.............................................................. | 3 | (STOP)
2. | (** IF NOT MIND-BODY, STOP **)
3. | Language of Abstract: | Circle One
3. | English.............................................................. | 1
3. | Indian (Specify:___________________)........ | 2
3. | German.............................................................. | 3
3. | Russian............................................................. | 4
3. | Other (Specify:___________________)........ | 5
3. | Don't Know..................................................... | 6
4. | Focus: | Yes | No
4. | Disease....................................................... | 1 | ......... 2
4. | Mind-Body Therapy................................ | 1 | ......... 2
4. | Other (Specify:___________________).... | 1 | ......... 2
4. | Unclear....................................................... | 1
5. | Body Systems: | Yes | No
5. | Circulatory/Cardio-vascular.................... | 1 | .......... 2
5. | Dermatology.............................................. | 1 | .......... 2
5. | Endocrine................................................... | 1 | .......... 1
5. | Gastrointestinal......................................... | 1 | .......... 2
5. | Genitourinary (GU)................................... | 1 | .......... 2
5. | Gynecology............................................... | 1 | .......... 2
5. | Head/eyes/ears/nose/throat................... | 1 | .......... 2
5. | Hematology............................................... | 1 | .......... 2
5. | Musculoskeletal........................................ | 1 | .......... 2
5. | Neuropsychiatric (addictions, stress)... | 1 | .......... 2
5. | Oncology................................................... | 1 | .......... 2
5. | Respiratory/Pulmonary............................ | 1 | .......... 2
5. | Rheumatologic.......................................... | 1 | .......... 2
5. | Other (Specify:___________________).... | 1 | .......... 2
5. | Unclear....................................................... | 1
6. | Outcomes: | Yes | No
6. | Behavioral.................................................. | 1 | .......... 2
6. | Change in disease state........................... | 1 | .......... 2
6. | Days lost from work................................. | 1 | .......... 2
6. | Length of stay........................................... | 1 | .......... 2
6. | Pain............................................................. | 1 | .......... 2
6. | Physical functioning................................ | 1 | .......... 2
6. | Physiological changes............................. | 1 | .......... 2
6. | Psychological............................................ | 1 | .......... 2
6. | Quality of Life............................................ | 1 | .......... 2
6. | Survival...................................................... | 1 | .......... 2
6. | Other (Specify:___________________).... | 1 | .......... 2
6. | Unclear....................................................... | 1
7. | Modalities: | Yes | No
7. | Behavioral.................................................. | 1 | .......... 2
7. | Biofeedback............................................... | 1 | .......... 2
7. | Cognitive.................................................... | 1 | .......... 2
7. | Complementary (non-specific)................ | 1 | .......... 2
7. | Imagery/visualization............................... | 1 | .......... 2
7. | Hypnosis.................................................... | 1 | .......... 2
7. | Meditation................................................. | 1 | .......... 2
7. | Placebo....................................................... | 1 | .......... 2
7. | Relaxation................................................... | 1 | .......... 2
7. | Other (Specify:___________________).... | 1 | .......... 2
7. | Unclear....................................................... | 1
8. | Subject Population: | Yes | No
8. | Human........................................................ | 1 | .......... 2
8. | Animal........................................................ | 1 | .......... 2
8. | In-vitro........................................................ | 1 | .......... 2
8. | Other (Specify:___________________).... | 1 | .......... 2
8. | Unclear....................................................... | 1
9. | Study Type: | Circle One
9. | Historical/Descriptive/System...................... | 1
9. | Pharmacological.............................................. | 2
9. | Clinical Study.................................................. | 3
9. | Other (Specify:___________________)........ | 4
9. | Unclear............................................................. | 5
10. | If Clinical Study, design: | Circle One
10. | Controlled Trial............................................... | 1
10. | Case Control.................................................... | 2
10. | Case Series....................................................... | 3
10. | Cohort............................................................... | 4
10. | Review.............................................................. | 5
10. | Unclear............................................................. | 6
10. | Not a clinical study......................................... | 7
11. | Is there a special reason the article should be ordered?
11. | [image] Yes - Specify in “notes” section below.
11. | [image] No, no special reason.
NOTES: