# Appendix A: Literature Search Strategies

## Search Methodology for Mind-Body

### Search #1: (Dated 12/15/99)

#### Databases Searched and Years of Coverage

MEDLINE | Jan 1966-Dec 1999
HealthSTAR | Jan 1975-Dec 1999
EMBASE | Jan 1974-Nov 1999
PsycINFO | Jan 1987-Dec 1999
Allied and Complementary Medicine | Jan 1984-Jan 1999
MANTIS | Jan 1980-Dec 1999
Social SciSearch | Jan 1972-Dec 1999
SciSearch | Jan 1974-Dec 1989
SciSearch^*^ | Jan 1990-Dec 1999

* NOTE - A sampling from this database indicated a large number of irrelevant items and so the database was not included in the final search - RS

#### Search Strategy

Note: A dash after a term indicates that the term was truncated (e.g. “hypno-“ will search “hypnosis,” “hypnotic,” “hypnotherapy,” etc.)

The word “exploded” in parentheses after a term indicates that the term was searched hierarchically - i.e. all narrower terms in the subject hierarchy were included. This feature is active in the MEDLINE, HealthSTAR, and EMBASE databases.

MIND-BODY RELATIONS (METAPHYSICS) FROM MEDLINE,HEALTHSTAR OR MINDBODY OR MIND(WITHIN 2 WORDS OF)BODY OR BODYMIND OR PLACEBO FROM PSYCHINFO,SOCIALSCISEARCH,SCISEARCH OR PLACEBO EFFECT FROM MEDLINE,HEALTHSTAR,ALLIED,MANTIS OR PSYCHONEUROIMMUNOLOG- OR RELAXATION TECHNIQUES(EXPLODED)FROM MEDLINE,HEALTHSTAR OR RELAXATION THERAPY FROM PSYCHINFO OR RELAXATION FROM EMBASE,ALLIED,MANTIS OR RELAXATION(WITHIN 2 WORDS OF)(TECHNIQUE- OR THERAP-) FROM SOCIALSCISEARCH, SCISEARCH OR MEDITATION FROM EMBASE, ALLIED,MANTIS,PSYCHINFO,SOCIALSCISEARCH,SCISEARCH OR IMAGERY (PSYCHOTHERAPY) FROM MEDLINE,HEALTHSTAR,ALLIED,MANTIS OR IMAGERY IN SUBJECT FIELD FROM PSYCHINFO OR HYPNOSIS(EXPLODED) FROM MEDLINE,HEALTHSTAR OR HYPNOTHERAPY OR HYPNOSIS OR HYPNOTI- OR SELF(WITHIN 2 WORDS OF)HYPNOSIS FROM EMBASE,PSYCHINFO,ALLIED, MANTIS,SOCIALSCISEARCH,SCISEARCH OR BIOFEEDBACK (PSYCHOLOGY) FROM MEDLINE,HEALTHSTAR,ALLIED,MANTIS OR BIOFEEDBACK FROM PSYCHINFO,EMBASE, SOCIALSCISEARCH,SCISEARCH OR WISDOM(WITHIN 3 WORDS OF)BODY OR SELF(WITHIN 1 WORD OF)HEALING OR HEALING(WITHIN 1 WORD OF)(FORCE- OR CONSCIOUSNESS) OR BIOPSYCHOSOCIAL? OR ALTERNATIVE MEDICINE FROM PSYCHINFO

##### AND

TREATMENT OUTCOME(EXPLODED) FROM MEDLINE,HEALTHSTAR,EMBASE OR OUTCOMES RESEARCH FROM EMBASE OR TREATMENT OUTCOMES FROM PSYCHINFO OR OUTCOME- FROM ALLIED,MANTIS,SOCIALSCISEARCH,SCISEARCH

Total number of items retrieved (including duplicates): 2801

Total number of items retrieved (excluding duplicates): 2474

## Search Methodology for Mind-Body - Gastrointestinal Conditions

### Search #1: (Dated 3/7/00)

NOTE: This search originally included MEDLINE, EMBASE, and the current file of SciSearch. However, it was decided to search those databases separately because it appeared that the terms “psychophysiology” and “placebo” produced too many false drops in those databases. Search #2 is the result of that decision. At a later time, it was decided to go back and run the term “psychophysiology” in these databases after all. That search methodology is shown in Search #3.

#### Databases Searched and Years of Coverage

HealthSTAR | 1975-1999
PsycINFO | 1887-Mar 2000
Allied and Complementary Medicine | 1984-1999 (Jan)
MANTIS | 1980-2000
Social SciSearch | 1972-2000
SciSearch | 1974-1989

#### Search Strategy

MIND-BODY RELATIONS (METAPHYSICS) FROM HEALTHSTAR OR MIND BODY OR MINDBODY OR BODYMIND OR PLACEBO- OR PSYCHONEUROIMMUNOLOG- OR PSYCHOPHYSIOLOG- OR PSYCHOPHYSIOLOGY(EXPLODED) FROM HEALTHSTAR OR PSYCHOSOMATIC- IN TITLE OR SUBJECT FIELDS FROM HEALTHSTAR,ALLIED & COMPLEMENTARY MEDICINE,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR RELAXATION TECHNIQUES(EXPLODED) FROM HEALTHSTAR OR RELAXATION THERAP- OR RELAXATION TECHNIQUE- OR RELAXATION FROM ALLIED,MANTIS OR MEDITAT- OR IMAGERY (PSYCHOTHERAPY) FROM HEALTHSTAR,ALLIED,MANTIS OR IMAGERY IN SUBJECT FIELD FROM PSYCINFO OR IMAGERY IN TITLE OR SUBJECT FIELD FROM SCISEARCH OR VISUALI- FROM TITLE OR SUBJECT FIELDS OR HYPNOSIS(EXPLODED) FROM HEALTHSTAR OR HYPNOSIS OR HYPNOTHERAPY OR HYPNOTI- OR BIOFEEDBACK (PSYCHOLOGY) FROM HEALTHSTAR,ALLIED,MANTIS OR BIOFEEDBACK OR WISDOM OF THE BODY OR SELF HEAL- OR HEALING FORCE- OR HEALING CONSCIOUSNESS OR BIOPSYCHOSOCIAL- OR ALTERNATIVE MEDICINE OR COMPLEMENTARY MEDICINE

##### AND

GASTROINTESTINAL DISEASES(EXPLODED) FROM HEALTHSTAR OR GASTROINTESTINAL DISORDERS FROM PSYCINFO OR (GASTROINTESTINAL OR DIGESTIVE OR GASTRIC OR GASTRITIS OR IRRITABLE BOWEL- OR PEPTIC ULCER- OR FECAL INCONTINEN- OR ENCOPRESIS OR COLON- NEOPLASM- OR COLON- CANCER OR ESOPHAG- REFLUX OR BOWEL OBSTRUCT- OR ILEUS OR DIVERTICUL- OR DYSPEPSI-) FROM ALLIED&COMPLEMENTARY MEDICINE,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR (HEPATITIS OR COLITIS OR CROHN- DISEASE OR GASTRIC CANCER- OR GASTRIC CARCINOMA- OR STOMACH CANCER OR STOMACH CARCINOMA- OR NAUSEA- OR VOMIT- OR MALDIGESTI- OR MALABSORPT- OR EMESIS OR INFLAMMATORY BOWEL- OR ABDOMINAL PAIN) FROM ALLIED & COMPLEMENTARY MEDICINE,PSYCINFO,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR COLON DISORDERS FROM PSYCINFO OR GASTROINTESTINAL ULCERS FROM PSYCINFO OR BACTERIAL OVERGROWTH OR CELIAC SPRUE OR CHOLECYSTITIS OR CHOLELITHIASIS OR GALLSTONE- OR (ESOPHAGEAL DIVERTICULUM(EXPLODED) OR STOMACH DIVERTICULUM(EXPLODED) OR DIVERTICULITIS OR NAUSEA(EXPLODED) OR DYSPEPSIA) FROM HEALTHSTAR

Total number of records retrieved: 1849

### Search #2: (Dated 4/5/00)

#### Databases Searched

MEDLINE
EMBASE
SciSearch (Current file)
Years of Coverage: 1980-2000

#### Search Strategy

MIND-BODY RELATIONS (METAPHYSICS) FROM MEDLINE OR MIND BODY OR MINDBODY OR BODYMIND OR PLACEBO EFFECT FROM MEDLINE OR PSYCHONEUROIMMUNOLOG- OR PSYCHOSOMATICS FROM EMBASE OR PSYCHOSOMATIC- IN TITLE OR SUBJECT FIELDS FROM MEDLINE, SCISEARCH OR RELAXATION TECHNIQUES(EXPLODED) FROM MEDLINE OR RELAXATION THERAP- FROM SCISEARCH OR RELAXATION TECHNIQUE- FROM SCISEARCH OR RELAXATION FROM EMBASE OR MEDITAT- OR IMAGERY (PSYCHOTHERAPY) FROM MEDLINE OR IMAGERY IN TITLE OR SUBJECT FIELD FROM EMBASE, SCISEARCH OR IMAGERY IN TITLE OR SUBJECT FIELD FROM SCISEARCH OR VISUALI- FROM TITLE OR SUBJECT FIELDS OR HYPNOSIS(EXPLODED) FROM MEDLINE OR HYPNOTHERAPY OR HYPNOSIS FROM EMBASE, SCISEARCH OR HYPNOTI- FROM EMBASE, SCISEARCH OR BIOFEEDBACK (PSYCHOLOGY) FROM MEDLINE OR BIOFEEDBACK FROM EMBASE, SCISEARCH OR WISDOM OF THE BODY OR SELF HEAL- OR HEALING FORCE- OR HEALING CONSCIOUSNESS OR BIOPSYCHOSOCIAL- OR ALTERNATIVE MEDICINE OR COMPLEMENTARY MEDICINE

##### AND

GASTROINTESTINAL DISEASES(EXPLODED) FROM MEDLINE OR DIGESTIVE SYSTEM DISEASE(EXPLODED) FROM EMBASE OR (GASTROINTESTINAL OR DIGESTIVE OR GASTRIC OR GASTRITIS OR IRRITABLE BOWEL- OR HEPATITIS OR COLITIS OR CROHN- DISEASE OR PEPTIC ULCER- OR FECAL INCONTINEN- OR ENCOPRESIS OR GASTRIC CANCER- OR GASTRIC CARCINOMA- OR STOMACH CANCER OR STOMACH CARCINOMA- OR ESOPHAG- REFLUX OR BOWEL OBSTRUCT- OR ILEUS OR DYSPEPSI- OR DIVERTICUL- OR NAUSEA- OR VOMIT- OR MALDIGESTI- OR MALABSORPT-) FROM SCISEARCH OR(HEPATITIS OR ENCOPRESIS OR GASTROESOPHAGEAL REFLUX OR ESOPHAGEAL DIVERTICULUM(EXPLODED) OR STOMACH DIVERTICULUM(EXPLODED OR NAUSEA(EXPLODED) OR DIVERTICULITIS OR DYSPEPSIA) FROM MEDLINE OR (DIVERTICULOSIS(EXPLODED) FROM EMBASE OR FECES INCONTINENCE FROM EMBASE OR NAUSEA IN TITLE,SUBJECT FIELD FROM EMBASE OR(EMESIS OR INFLAMMATORY BOWEL- OR ABDOMINAL PAIN) FROM EMBASE,SCISEARCH OR BACTERIAL OVERGROWTH OR CELIAC SPRUE OR CHOLECYSTITIS OR CHOLELITHIASIS OR GALLSTONE

Total number of records retrieved: 4216

### Search #3 (Dated 7/18/00)

#### Databases Searched And Years Of Coverage

MEDLINE | 1980-2000
EMBASE | 1980-2000
SciSearch (Current) | 1990-2000

#### Search Strategy

PSYCHOPHYSIOLOGY! (MAJOR TERM EXPLODED) FROM MEDLINE, EMBASE OR PSYCHOPHYSIOLOG- FROM SCISEARCH

##### AND

GASTROINTESTINAL DISEASES(EXPLODED) FROM MEDLINE OR DIGESTIVE SYSTEM DISEASE(EXPLODED) FROM EMBASE OR (GASTROINTESTINAL OR DIGESTIVE OR GASTRIC OR GASTRITIS OR IRRITABLE BOWEL- OR HEPATITIS OR COLITIS OR CROHN- DISEASE OR PEPTIC ULCER- OR FECAL INCONTINEN- OR ENCOPRESIS OR GASTRIC CANCER- OR GASTRIC CARCINOMA- OR STOMACH CANCER OR STOMACH CARCINOMA- OR ESOPHAG- REFLUX OR BOWEL OBSTRUCT- OR ILEUS OR DYSPEPSI- OR DIVERTICUL- OR NAUSEA- OR VOMIT- OR MALDIGESTI- OR MALABSORPT-) FROM SCISEARCH OR (HEPATITIS OR ENCOPRESIS OR GASTROESOPHAGEAL REFLUX OR ESOPHAGEAL DIVERTICULUM(EXPLODED) OR STOMACH DIVERTICULUM(EXPLODED OR NAUSEA(EXPLODED) OR DIVERTICULITIS OR DYSPEPSIA) FROM MEDLINE OR (DIVERTICULOSIS(EXPLODED) FROM EMBASE OR FECES INCONTINENCE FROM EMBASE OR NAUSEA IN TITLE,SUBJECT FIELD FROM EMBASE - OR (EMESIS OR INFLAMMATORY BOWEL- OR ABDOMINAL PAIN) FROM EMBASE,SCISEARCH OR BACTERIAL OVERGROWTH OR CELIAC SPRUE OR CHOLECYSTITIS OR CHOLELITHIASIS OR GALLSTONE

Total number of records retrieved: 4849

### Search #4 (Dated 8/4/00)

#### Databases Searched And Years Of Coverage

CINAHL | 1982-2000

#### Search Strategy

MIND BODY OR MINDBODY OR BRAIN GUT OR PSYCHOPHYSIOLOG- OR PSYCHOSOMATIC- OR PLACEBO EFFECT- OR PSYCHONEUROIMMUNOLOG- OR RELAX- OR MEDITAT- OR IMAGERY OR VISUALI- OR HYPNO- OR BIOFEEDBACK OR WISDOM OF THE BODY OR SELF HEAL- OR HEAL- FORCE OR HEAL- CONSCIOUS- OR BIOPSYCHOSOCIAL OR ALTERNATIVE THERAP- OR ALLOPATHIC OR ALTERNATIVE HEALTH PERSONNEL OR COMPLEMENTARY MEDICINE

##### AND

GASTROINTESTINAL OR DIGESTIVE OR GASTRI- OR INTESTIN- OR BOWEL- OR HEPATITIS OR COLITIS OR CROHN- OR ULCER- OR INCONTINEN- OR ENCOPRESIS OR STOMACH OR COLON OR COLONIC OR ESOPHAG- OR ILEUS OR DYSPEP- OR DIVERTICU- OR NAUSEA- OR VOMIT- OR MALDIGEST- OR MALABSORPT- OR BACTERIAL OVERGROWTH OR CELIAC SPRUE OR CHOLECYSTITIS OR CHOLELITHIASIS OR GALLSTONE- OR EMESIS OR ABDOMINAL PAIN- OR REFLUX

Total number of records retrieved: 1357

### Search #5 (Dated 8/31/00)

#### Databases Searched And Years Of Coverage

MEDLINE | 1966-2000
HealthSTAR | 1975-2000
PsycINFO | 1887-2000
Allied & Alternative Medicine(AMED) | 1984-2000
MANTIS | 1880-2000
EMBASE | 1974-2000
Social SciSearch | 1972-2000
SciSearch (Current) | 1990-2000
SciSearch (Archival) | 1974-1989

#### Search Strategy

BRAIN GUT OR MIND GUT

Total number of records retrieved: 702

## Search Methodology Mind-Body Cardiovascular

### Search #1 (Dated 8/25/00)

#### Databases Searched And Years Of Coverage

MEDLINE | 1966-2000
HealthSTAR | 1975-2000
PsycINFO | 1887-2000
Allied & Alternative Medicine(AMED) | 1984-2000
MANTIS | 1880-2000
EMBASE | 1974-2000
Social SciSearch | 1972-2000
SciSearch (Current) | 1990-2000
SciSearch (Archival) | 1974-1989

#### Search Strategy

MIND-BODY RELATIONS (METAPHYSICS) FROM MEDLINE,HEALTHSTAR OR MINDBODY OR MIND BODY OR BODYMIND OR PSYCHOPHYSIOLOGY(EXPLODED) FROM MEDLINE,HEALTHSTAR,EMBASE OR PSYCHOPHYSIOLOG- FROM PSYCINFO,ALLIED&ALTERNATIVE MEDICINE,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR PSYCHOSOMATICS FROM EMBASE OR PSYCHOSOMATIC- IN TITLE, SUBJECT HEADING FROM MEDLINE,HEALTHSTAR,PSYCINFO,ALLIED & ALTERNATIVE MEDICINE,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR PLACEBO EFFECT FROM MEDLINE,HEALTHSTAR,ALLIED & ALTERNATIVE MEDICINE,MANTIS OR PLACEBO- FROM PSYCINFO, SOCIAL SCISEARCH,SCISEARCH OR PSYCHONEUROIMMUNOLOG- OR RELAXATION TECHNIQUES(EXPLODED) FROM MEDLINE,HEALTHSTAR OR RELAXATION THERAPY FROM PSYCINFO OR RELAXATION IN TITLE, SUBJECT HEADING FROM EMBASE,ALLIED,MANTIS OR (RELAXATION TECHNIQUE- OR RELAXATION THERAP- OR RELAXATION TREAT-) FROM SOCIAL SCISEARCH,SCISEARCH OR MEDITAT- FROM EMBASE, PSYCINFO,ALLIED & ALTERNATIVE MEDICINE,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR IMAGERY (PSYCHOTHERAPY) FROM MEDLINE,HEALTHSTAR,ALLIED,MANTIS OR IMAGERY IN SUBJECT HEADING FROM PSYCINFO OR GUIDED IMAGERY FROM SOCIAL SCISEARCH,SCISEARCH OR BIOFEEDBACK (PSYCHOLOGY) FROM MEDLINE,HEALTHSTAR,ALLIED,MANTIS OR BIOFEEDBACK FROM PSYCINFO,EMBASE,SOCIAL SCISEARCH,SCISEARCH OR WISDOM OF THE BODY OR SELF HEALING OR HEALING FORCE- OR HEALING CONSCIOUSNESS OR BIOPSYCHOSOCIAL- OR VISUALIZATION IN TITLE,SUBJECT HEADING OR HYPNOSIS(EXPLODED) FROM MEDLINE,HEALTHSTAR OR HYPNOSIS OR HYPNOTI- OR SELF-HYPNOSIS OR ALTERNATIVE MEDICINE FROM PSYCINFO

##### AND

TREATMENT OUTCOME(EXPLODED) FROM MEDLINE,HEALTHSTAR,EMBASE OR OUTCOMES RESEARCH FROM EMBASE OR TREATMENT OUTCOMES FROM PSYCINFO OR OUTCOME- FROM ALLIED,MANTIS,SOCIAL SCISEARCH,SCISEARCH

##### AND

CARDIOVASCULAR DISEASE-(EXPLODED) FROM MEDLINE,HEALTHSTAR,EMBASE OR CARDIOVASCULAR DISORDERS FROM PSYCINFO OR THORACIC SURGICAL PROCEDURES FROM MEDLINE,HEALTHSTAR OR CARDIOVASCULAR SURGERY(EXPLODED) FROM EMBASE OR HEART SURGERY FROM PSYCINFO OR ((CARDIOVASCULAR OR HEART) WITHIN 2 WORDS OF (DISEASE- OR DISORDER- OR ATTACK- OR FAILURE OR VALVE- OR SURGERY) OR ARRYTHMIA- OR CARDIOMEGAL- OR ENDOCARDITIS OR MYOCARDIA- OR PRECARDI- OR CORONARY ARTER- OR CHEST PAIN OR ANGINA OR TACHYCARDI- OR CARDIOTHORAC- OR PALPITATION- OR RAYNAUD- OR (CEREBROVASCULAR OR VASCULAR OR AORTIC OR AORTA) WITHIN 2 WORDS OF (DISEASE- OR DISORDER-) OR STROKE- OR HYPERTENS- OR HIGH BLOOD PRESSURE OR HYPOTENS- OR VARICOSE VEIN- OR VASCULITIS OR VENOUS INSUFFICIEN- OR MITRAL VALVE- OR DIZZY OR DIZZINESS OR VERTIGO OR ACROCYANOSIS OR TINNITUS OR SYNCOPE)) FROM PSYCINFO,ALLIED,MANTIS,SOCIAL SCISEARCH,SCISEARCH OR SYNCOPE(EXPLODED) FROM MEDLINE,HEALTHSTAR,EMBASE OR POOR CIRCULATION OR COLD LIMB- OR COLD HAND- OR COLD FOOT OR COLD FEET

Total number of records retrieved: 2388