# Appendixes

Appendix A: Literature Search Strategies

Appendix B: Short Screening Form

Appendix C: Long Screening Form