# Acknowledgments

## Evidence Report Staff

- AHCPR Program Director
- Naomi Aronson, Ph.D.

- Systematic Review
- Jerome Seidenfeld, Ph.D., Project Director
- David J. Samson

- Meta-Analysis
- Victor Hasselblad, Ph.D.

- Cost-Effective Analysis
- Alan M. Garber, M.D., Ph.D.
- Adalsteinn Brown, A.B.
- Ahmed M. Bayoumi, M.D., M.Sc.

- Research/Editorial Staff
- Claudia J. Bonnell, B.S.N., M.L.S.
- Maurice Carter
- Maxine Gere, M.S.
- Lori D. Nickel
- Katheleen M. Ziegler, Pharm.D.

## Technical Advisory Group

- Peter C. Albertsen, M.D.
- University of Connecticut Health Center
- Division of Urology

- Charles Bennett, M.D., Ph.D.
- Institute for Health Services Research
- Northwestern University

- Alan M. Garber, M.D., Ph.D.
- Stanford University School of Medicine;
- Division of General Internal Medicine

- Victor Hasselblad, Ph.D.
- Duke Clinical Research Institute
- Duke University

- Timothy J. Wilt, M.D., M.P.H.
- Section of General Medicine
- Minneapolis VA Medical Center

## External Expert Reviewers

- Alex A. Adjei, M.D., Ph.D.
- Mayo Clinic

- Grant P. Bagley, M.D.
- Director, Coverage & Analysis Group
- Health Care Financing Administration

- Otis Brawley, M.D. a
- Director, Office of Special Populations, NCI

- Dr. Otilia Dalesio a
- Department of Biometrics,
- Netherlands Cancer Institute
- Prostate Cancer Trialists' Collaborative Group

- Chester Good, M.D., M.P.H.
- Pittsburgh VA Medical Center

- Manny Hamelburg
- Patient Representative nominated by the American Foundation for Urologic Diseases

- H. Logan Holtgrewe, M.D.
- Chair, Health Policy Council
- American Urological Association

- Gary Huckabay, Ph.D. a
- Cameron University
- Patient Representative nominated by the National Prostate Cancer Coalition

- Deborah A. Kuban, M.D.
- Eastern Virginia Medical School
- Nominated by the American Society for Therapeutic Radiology and Oncology

- Philip W. Kantoff
- Dana-Farber Cancer Institute
- Lank Center for Genitourinary Oncology

- Joseph Lau, M.D.
- Division of Clinical Care Research
- New England Medical Center
- EPC Project Director

- Henry A. Porterfield
- Patient Representative nominated by US TOO International

- Ian M. Thompson, Jr., M.D.
- Brook Army Medical Center

- John H. Wasson, M.D.
- Prostate Patient Outcomes Research Team
- Dartmouth Medical School

- Patrick C. Walsh, M.D.
- Urologist-in-Chief
- James Buchanan Brady Urological Institute
- The Johns Hopkins Hospital
- Nominated by the American Urological Association

- Jane Weeks, M.D.
- Dana-Farber Cancer Institute

- Nicholas J. Vogelzang, M.D.
- University of Chicago, Medical Center
- Section of Hematology/Oncology
- Nominated by the American Society of Clinical Oncology

- Anthony Zeitman, M.D.
- Massachusetts General Hospital
- Department of Radiation Oncology

- Pharmaceutical Companies
- Brian McMaster, RPh
- Hoescht Marion Roussel Canada

- Lisa Porter, M.D.
- Zeneca Pharmaceuticals

- Brian Niemi, RPh a
- TAP Pharmaceuticals

- Lily Chen, Pharm.D.
- Schering Laboratories

- John Wodtke, RPh a
- Hoeschst Marion Roussel

## Blue Cross and Blue Shield Association Medical Advisory Panel

- Peter C. Albertsen, M.D.
- University of Connecticut Health Center
- Division of Urology

- James O. Armitage, M.D.
- University of Nebraska Medical Center
- Chairman Department of Internal Medicine

- Wade Aubry, M.D. (Chair)
- Blue Cross and Blue Shield Association
- National Medical Consultant

- J. Lawrence Colley, M.D.
- Corporate Medical Director
- Trigon Blue Cross Blue Shield

- Helen Darling, M.A.
- Practice Leader, Group Benefits & Health Care
- Watson Wyatt & Company

- Richard D. Dent, M.D.
- Blue Cross & Blue Shield of the Rochester Area
- Senior Vice President, Managed Care

- David M. Eddy, M.D., Ph.D.
- Kaiser Permanente
- Southern California Region
- Scientific Advisor for Health Policy and Management

- Alan M. Garber, M.D., Ph.D.
- Stanford Medical School
- Associate Professor of Medicine

- Kathleen Goonan, M.D.
- Blue Cross and Blue Shield of Massachusetts
- Vice President, Health Affairs

- Michael A. W. Hattwick, M.D.
- Woodburn Internal Medicine Associates, Ltd.

- I. Craig Henderson, M.D.
- University of California, San Francisco
- Professor of Medicine, Chief of Oncology

- Albert R. Jonsen, Ph.D.
- University of Washington
- Department of Medical History and Ethics

- Peter A. Margolis, M.D., Ph.D.
- University of North Carolina
- Department of Pediatrics, Assistant Professor
- Department of Epidemiology, Clinical Professor

- Barbara J. McNeil, M.D., Ph.D.
- Harvard Medical School
- Department of Health Care Policy
- Head of Health Care Policy

- Richard G. Roberts, M.D., J.D.
- University of Wisconsin School of Medicine
- Department of Family Medicine

- Earl P. Steinberg, M.D., M.P.P.
- Covance Health Economics & Outcomes Services, Inc.

- Clifford Waldman, M.D.
- Anthem Blue Cross & Blue Shield
- Medical Director

- Paul J. Wallace, M.D.
- Kaiser Permanente Northwest

- Les Zendle, M.D.
- Kaiser Permanente Southern California
- Associate Medical Director