# Bibliography

Airhart RA, Barnett TF, Sullivan JW, Levine RL, Schlegel JU. Flutamide therapy for carcinoma of the prostate. South Med J. 1978 Jul;71(7):798-801.
Akaza H, Isaka S, Usami M, Kanetake H, Kotake T, Koiso K, Aso Y. Recommended dose of flutamide with LH-RH agonist therapy in patients with advanced prostate cancer. Int J Urol. 1996 Nov;3(6):468-71.
Akaza H, Usami M, Kotake T, Koiso K, Aso Y. A randomized phase II trial of flutamide vs chlormadinone acetate in previously untreated advanced prostatic cancer. The Japan Flutamide Study Group. Jpn J Clin Oncol. 1993 Jun;23(3):178-85.
Albertsen PC. Early-stage prostate cancer. When is observation appropriate?. Hematol Oncol Clin North Am. 1996 Jun;10(3):611-25. [pmid: 8773500].
Albertsen PC, Aaronson NK, Muller MJ, Keller SD, Ware JE, Jr. Health-related quality of life among patients with metastatic prostate cancer. Urology. 1997 Feb;49(2):207-16; discussion 216-7. [pmcid: 140032].
Albertsen PC, Fryback DG, Storer BE, Kolon TF, Fine J. Long-term survival among men with conservatively treated localized prostate cancer. JAMA. 1995 Aug 23-30;274(8):626-31.
Alivizatos G, Oosterhof GO. Update of hormonal treatment in cancer of the prostate. Anticancer Drugs. 1993 Jun;4(3):301-9.
American College of Physicians. Screening for prostate cancer. Ann Intern Med. 1997 Mar 15;126(6):480-4.
American Joint Committee on Cancer. Prostate. In: Manual for staging of cancer. 4th ed. Philadelphia: JB Lippincott Co; 1992. p. 181-3.
Andersson L, editor. Design of clinical trials on prostate cancer. Urology. 1997 Apr;49(4A Suppl):1-76. [pmcid: 140032].
Anonymous. 3rd International Workshop on Randomized Trials on Maximal Androgen Blockade in M1 Prostate Cancer Patients. Proceedings. Paris, France, June 19, 1992. Cancer. 1993;72(12 Suppl):3781-895. [pmid: 7902778].
Anonymous. Cancer of the prostate. N Engl J Med. 1968 Apr 11;278(15):848-9.
Anonymous. Carcinoma of the prostate: Treatment comparisons. J Urol. 1967 Oct;98(4):516-22.
Anonymous. Carcinoma of the prostate. Analysis of patient morbidity at the 6-month, 12-month and 18-month follow-up examinations. J Chronic Dis. 1964;17(3):207-23.
Anonymous. Choice of gonadorelin agonist for a given indication depends on the formulation. Drugs Ther Perspectives. 1995;6(2):1-4.
Anonymous. Flutamide for prostate cancer. Med Lett Drugs Ther. 1989 Jul 28;31(797).
Anonymous. Hormone therapy and prostate cancer. J Urol. 1991;97(6).
Anonymous. ICI-176334. Bicalutamide. Casodex. Drugs Future. 1994;19(3):293-4.
Anonymous. ICI-176334. Casodex. Drugs Future. 1992;17(3):247-8.
Anonymous. Ketoconazole in Cushing's syndrome and metastatic prostate cancer. Prescrire Intl. 1997;6(30):105-7.
Anonymous. Less toxic, more convenient therapy being touted for patients with advanced prostate cancer. Formulary. 1995;30(7).
Anonymous. Leuprolide for prostate cancer. Med Lett Drugs Ther. 1985;27(694):71-2. [pmid: 2410765].
Anonymous. Lupron depot-3 month 11.25 Mg: Smaller dose of 3-month formulation. Formulary. 1997;32(7).
Anonymous. Lupron depot-4 month 30 mg. Formulary. 1997;32(9).
Anonymous. [Significance of intensive follow-up in patients with advanced prostatic carcinoma undergoing hormonal treatment]. Minerva Urol Nefrol. 1994 Jun;46(2):XVI-XVII.
Anonymous. Zoladex and cancer of the prostate. Subcutaneous implantation of a LHRH analog. Concours Med. 1990;112(28).
Aro J. Cardiovascular and all-cause mortality in prostatic cancer patients treated with estrogens or orchiectomy as compared to the standard population. Prostate. 1991;18(2):131-7. [pmid: 2006119].
Aro J, Haapiainen R, Kati M, Rannikko S, Alfthan O. Orchiectomy, estrogen therapy and radiotherapy in locally advanced (T3-4 M0) prostatic cancer. Scand J Urol Nephrol Suppl. 1988;110:103-7. [pmid: 3187397].
Aso Y, Akaza H, Koiso K, Kumamoto Y, Kawai T, Origasa S, Hosaka M, Yamanaka H, Shimazaki J, Fuse H, et al. Phase I study of flutamide, a nonsteroidal antiandrogen, in patients with prostatic cancer. Hinyokika Kiyo. 1993;39(4):381-9. [pmid: 8503338].
Aso Y, Kameyama S, Niijima T, Ohmori H, Ohashi T, Murahashi I, Akimoto M, Koiso K, Akaza H, Hosaka M, et al. [Clinical phase III study on TAP-144-SR, an LH-RH agonist depot formulation, in patients with prostatic cancer]. Hinyokika Kiyo. 1991 Mar;37(3):305-20.
Atala A, Amin M. Current concepts in the treatment of genitourinary tract disorders in the older individual. Drugs Aging. 1991 May;1(3):176-93.
Bailar JC 3d, Byar DP. Estrogen treatment for cancer of the prostate. Early results with 3 doses of diethylstilbestrol and placebo. Cancer. 1970 Aug;26(2):257-61.
Balducci L, Pow-Sang J, Friedland J, Diaz JI. Prostate cancer. Clin Geriatr Med. 1997 May;13(2):283-306.
Bales GT, Chodak GW. A controlled trial of bicalutamide versus castration in patients with advanced prostate cancer. Urology. 1996 Jan;47(1A Suppl):38-43.
Barradell LB, Faulds D. Cyproterone. A review of its pharmacology and therapeutic efficacy in prostate cancer. Drugs Aging. 1994 Jul;5(1):59-80.
Bayard S, Greenberg R, Showalter D, Byar D. Comparison of treatments for prostatic cancer using an exponential-type life model relating survival to concomitant information. Cancer Chemother Rep. 1974 Nov;58(6):845-59.
Beck JR, Pauker SG. The Markov process in medical prognosis. Med Decis Making. 1983;3(4):419-58. [pmid: 6668990].
Beland G. Combination of Anandron with orchiectomy in treatment of metastatic prostate cancer. Results of a double-blind study. Urology. 1991;37(2 Suppl):25-9. [pmid: 1992600].
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey E, Trachtenberg J, Tewari H, Venner P. Total androgen ablation versus castration in the treatment of metastatic prostatic cancer [abstract]. In: International Testicular and Prostatic Cancer Conference; 1990b Oct 4-6; Toronto, Canada. p. 92.
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM. Total androgen blockade for metastatic cancer of the prostate. Am J Clin Oncol. 1988;11(Suppl 2):S187-90. [pmid: 3149456].
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM, Tewari HD. A controlled trial of castration with and without nilutamide in metastatic prostatic carcinoma. Cancer. 1990 Sep 1;66(5 Suppl):1074-9.
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM, Tewari HD. Total androgen ablation: Canadian experience. Urol Clin North Am. 1991 Feb;18(1):75-82.
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Venner PM, Tewari HD. Total androgen blockade vs orchiectomy in stage D2 prostate cancer. Prog Clin Biol Res. 1987;243A:391-400. [pmid: 3116550].
Bennett AH, Dowd JB, Harrison JH. Estrogen and survival data in carcinoma of the prostate. Surg Gynecol Obstet. 1970 Mar;130(3):505-8.
Bennett CL, Matchar D, McCrory D, McLeod DG, Crawford ED, Hillner BE. Cost-effective models for flutamide for prostate carcinoma patients: are they helpful to policy makers?. Cancer. 1996 May 1;77(9):1854-61.
Benson RC. Total androgen blockade: The United States experience. Eur Urol. 1993;24(Suppl 2):72-6. [pmid: 8262130].
Benson RC Jr, Crawford ED, Eisenberger MA, McLeod DG, Spaulding JT, Dorr FA. National Cancer Institute study of luteinizing hormone-releasing hormone plus flutamide versus luteinizing hormone-releasing hormone plus placebo. Semin Oncol. 1991 Oct;18(5 Suppl 6):9-12.
Jorgensen T, Berner A, Kaalhus O, Tveter KJ, Danielsen HE, Bryne M. Up-regulation of oligosaccharide sialyl LewisX in metastatic prostate cancer [abstract]. J Pathol. 1995;176(Suppl).
Bertagna C, De Gery A, Hucher M, Francois JP, Zanirato J. Efficacy of the combination of nilutamide plus orchidectomy in patients with metastatic prostatic cancer. A meta-analysis of seven randomized double-blind trials (1056 patients). Br J Urol. 1994 Apr;73(4):396-402.
Bianchi G, Beltrami P, Motta L, Mobilio G. Total androgenic blockade: A review. Acta Urol Belg. 1995 Sep;63(3):11-9.
Bischoff W. 3.75 and 7.5 mg leuprorelin acetate depot in the treatment of advanced prostatic cancer: Preliminary report. German Leuprorelin Study Group. J Int Med Res. 1990;18(Suppl 1):103-13. [pmid: 2108882].
Bishop MC. Experience with low-dose oestrogen in the treatment of advanced prostate cancer: A personal view. Br J Urol. 1996 Dec;78(6):921-7. [pmid: 9014720].
Bishop MC. Treatment of advanced prostate cancer. Lancet. 1994 Jan 8;343(8889):110-1. [pmid: 7903736].
Black WC, Nease RF, Welch G. Determining transition probabilities from mortality rates and autopsy findings. Med Decis Making. 1997 Jan;17(1):87-93.
Blackard CE. Treatment of advanced carcinoma of the prostate. Surg Gynecol Obstet. 1971 Jul;133(1):97-8. [pmid: 5091832].
Blackard CE. Re: Deferred treatment of low grade stage T3 prostate cancer without distant metastases. J Urol. 1994 Feb;151(2).
Blackard CE, Byar DP, Jordan WP Jr. Orchiectomy for advanced prostatic carcinoma. A reevaluation. Urology. 1973 Jun;1(6):553-60. [pmcid: 111060].
Blackard CE, Byar DP, Seal US, Doe RP. Correlation of pretreatment serum nonprotein-bound cortisol and total 17-hydroxycorticosteroid values with survival in patients with prostatic cancer. N Engl J Med. 1974 Oct 10;291(15):751-5.
Blackard CE, Doe RP, Mellinger GT, Byar DP. Incidence of cardiovascular disease and death in patients receiving diethylstilbestrol for carcinoma of the prostate. Cancer. 1970 Aug;26(2):249-56.
Blackard CE, Doe RP, Seal US. Serum corticosteroid-binding globulin, cortisol, and nonprotein-bound cortisol levels in patients receiving estrogen for carcinoma of the prostate. Invest Urol. 1973 Nov;11(3):194-7.
Blackard CE, Mellinger GT. Current status of estrogen therapy for prostatic carcinoma. Postgrad Med. 1972 Mar;51(3):140-5.
Blackledge G. Casodex--mechanisms of action and opportunities for usage. Cancer. 1993 Dec 15;72(12 Suppl):3830-3. [pmid: 7504578].
Blackledge G, Kolvenbag G, Nash A. Bicalutamide: A new antiandrogen for use in combination with castration for patients with advanced prostate cancer. Anticancer Drugs. 1996 Jan;7(1):27-34.
Blackledge GR. Clinical progress with a new antiandrogen, Casodex (bicalutamide). Eur Urol. 1996;29(Suppl 2):96-104. [pmid: 8717470].
Blackledge GR. High-dose bicalutamide monotherapy for the treatment of prostate cancer. Urology. 1996 Jan;47(1A Suppl):44-7. [pmid: 8560678].
Blackledge GR, Cockshott ID, Furr BJ. Casodex (bicalutamide): overview of a new antiandrogen developed for the treatment of prostate cancer. Eur Urol. 1997;31(Suppl 2):30-9.
Blackledge GR, Lowery K. Role of prostate-specific antigen as a predictor of outcome in prostate cancer. Prostate. 1994;24(Suppl 5):34-8.
Blue Cross and Blue Shield Association. Brachytherapy for prostate cancer. Technology Evaluation Center (TEC) Assessment Program. 1997 Jun;12(5):1-28. [pmcid: 169025].
Boccardo F, Decensi A, Guarneri D, Rubagotti A, Massa T, Martorana G, Giberti C, Cerruti G B, Tani F, Zanollo A, et al. Long-term results with a long-acting formulation of D-TRP-6 LH-RH in patients with prostate cancer: An Italian prostatic cancer project (P.O.N.C.A.P.) study. Prostate. 1987;11(3):243-55. [pmid: 2960957].
Boccardo F, Decensi A, Guarneri D, Rubagotti A, Oneto F, Martorana G, Giuliani L, Delli Ponti U, Petracco S, Cortellini P et al. Zoladex with or without flutamide in the treatment of locally advanced or metastatic prostate cancer: Interim analysis of an ongoing PONCAP study. Italian Prostatic Cancer Project (PONCAP). Eur Urol. 1990;18(Suppl 3):48-53.
Boccardo F, Guarneri D, Decensi A, Calabria C, Rubagotti A, Oneto F, Martorana G, Giuliani L, Cortellini P, Ziveri M, et al. Zoladex +/- flutamide in stage C and D prostatic CA patients. Preliminary results of multicenter Italian study [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1990;9.
Boccardo F, Pace M, Rubagotti A, Guarneri D, Decensi A, Oneto F, Martorana G, Giuliani L, Selvaggi F, Battaglia M, et al. Goserelin acetate with or without flutamide in the treatment of patients with locally advanced or metastatic prostate cancer. The Italian Prostatic Cancer Project (PONCAP) Study Group. Eur J Cancer. 1993;29A(8):1088-93. [pmid: 8518017].
Boccon-Gibod L. Maximum androgen blockade in 1996. Eur Urol. 1996;30(Suppl 1):15-8. [pmid: 8977985].
Boccon-Gibod L, Fournier G, Bottet P, Marechal JM, Guiter J, Rischman P, Hubert J, Soret JY, Mangin P, Mallo C, et al. Flutamide versus orchidectomy in the treatment of metastatic prostate carcinoma. Eur Urol. 1997;32(4):391-5. [pmid: 9412794].
Bolla M. [Cancer of the prostate: therapeutic trials in 1985]. Bull Cancer (Paris). 1986;73(1):74-80. [pmid: 3535935].
Bolla M, Bartelink H, Gibbons R, et al. Treatment of regional disease. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 259-66.
Bolla M, Gonzalez D, Warde P, Dubois J B, Mirimanoff R, Storme G, Bernier J, Kuten A, Sternberg C, Mattelaer J, et al. Immediate hormonal therapy improves locoregional control and survival in patients with locally advanced prostate cancer. Results of a randomized phase III clinical trial of the EORTC radiotherapy and genitourinary tract cancer cooperative groups [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Bolla M, Gonzalez D, Warde P, Dubois JB, Mirimanoff R-O, Storme G, Bernier J, Kuten A, Sternberg C, Gil T, et al. Improved survival in patients with locally advanced prostate cancer treated with radiotherapy and goserelin. N Engl J Med. 1997 Jul 31;337(5):295-300.
Bono AV, DiSilverio F, Robustelli della Cuna G, Benvenuti C, Brausi M, Ferrari P, Gibba A, Galli L. Complete androgen blockade versus chemical castration in advanced prostatic cancer: Analysis of an Italian multicentre study. Italian Leuprorelin Group. Urol Int. 1998;60(Suppl 1):18-24.
Botto H, Richard F, Mathieu F, Camey M. Decapeptyl in the treatment of advanced prostatic cancer: comparative study with pulpectomy. Prog Clin Biol Res. 1989;303:53-60. [pmid: 2528740].
Bouffioux C. Total androgen blockade in advanced prostatic cancer. Critical review and personal experience. Eur Urol. 1988;15(3-4):187-92. [pmid: 2975222].
Bouffioux C, Focan C, Desirotte J, Andrianne R, de Leval J, Doupagne M, Franchimont P. [Treatment of cancer of the prostate with Zoladex Depot]. Rev Med Liege. 1986 May 15;41(10):438-45.
Boyer M. The management of prostate cancer. Aust Prescriber. 1996;19(1):22-4.
Boyle P, Napalkov P, Barry MJ, et al. Epidemiology and natural history of prostate cancer. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 1-29.
Brisset JM, Bertagna C, Fiet J, de Gery A, Hucher M, Husson JM, Tremblay D, Raynaud JP. Total androgen blockade vs orchiectomy in stage D prostate cancer. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:17-30.
Brisset JM, Boccon-Gibod L, Botto H, Camey M, Cariou G, Duclos JM, Duval F, Gonties D, Jorest R, Lamy L, et al. Anandron (RU 23908) associated to surgical castration in previously untreated stage D prostate cancer: A multicenter comparative study of two doses of the drug and of a placebo. Prog Clin Biol Res. 1987;243A:411-22. [pmid: 3309973].
Brogden RN, Buckley MM, Ward A. Buserelin. A review of its pharmacodynamic and pharmacokinetic properties, and clinical profile. Drugs. 1990 Mar;39(3):399-437.
Brogden RN, Chrisp P. Flutamide. A review of its pharmacodynamic and pharmacokinetic properties, and therapeutic use in advanced prostatic cancer. Drugs Aging. 1991 Mar;1(2):104-15.
Brogden RN, Clissold SP. Flutamide. A preliminary review of its pharmacodynamic and pharmacokinetic properties, and therapeutic efficacy in advanced prostatic cancer. Drugs. 1989 Aug;38(2):185-203.
Bruchovsky N, Goldenberg SL, Gleave M, Rennie P, Akakura K, Sato N. Intermittent therapy for prostate cancer. Endocr Rel Cancer. 1997;4(2):153-77.
Bruchovsky N, Goldenberg SL, Rennie PS, Gleave M. [Theoretical considerations and initial clinical results of intermittent hormone treatment of patients with advanced prostatic carcinoma]. Urologe A. 1995 Sep;34(5):389-92.
Bruun E, Frimodt-Moller C for the Danish Buserelin Study Group. The effect of buserelin versus conventional antiandrogenic treatment in patients with T2-4NXM1 prostatic cancer: A prospective, randomized multicentre phase III trial. Scand J Urol Nephrol. 1996 Aug;30(4):291-7.
Bubley GJ, Balk SP. Treatment of metastatic prostate cancer. Lessons from the androgen receptor. Hematol Oncol Clin North Am. 1996 Jun;10(3):713-25.
Burchardt P, Agrapidakis J. [Liver and kidney function following oral administration of the anti-androgen cyproteron-acetate]. Urologe A. 1972 Sep;11(5):293-4.
Byar DP, Corle DK. Hormone therapy for prostate cancer: Results of the Veterans Administration Cooperative Urologic Research Group studies. Natl Cancer Inst Monogr. 1988;(7):165-70.
Byar DP. Assessing apparent treatment -- covariate interactions in randomized clinical trials. Stat Med. 1985 Jul;4(3):255-63. [pmid: 4059716].
Byar DP. Proceedings: The Veterans Administration Cooperative Urological Research Group's studies of cancer of the prostate. Cancer. 1973 Nov;32(5):1126-30. [pmid: 4585929].
Byar DP. Review of the Veterans Administration studies of cancer of the prostate and new results concerning treatment of stage I and II tumours. In: Pavone-Macaluso M, editor. Bladder tumors and other topics in urological oncology. Vol. 1. Plenum Press, Ettore Majorana International Science Series (Life Sciences); 1980.
Byar DP, Corle DK. Analysis of prognostic factors for prostatic cancer in the VACURG studies. Monogr Ser Eur Organ Res Treat Cancer. 1984;13:147-69.
Byar DP, Corle DK. Selecting optimal treatment in clinical trials using covariate information. J Chronic Dis. 1977;30(7):445-59. [pmid: 885985].
Byar DP, Green SB. The choice of treatment for cancer patients based on covariate information. Bull Cancer (Paris). 1980;67(4):477-90. [pmid: 7013866].
Cantor S. Cost-effectiveness analysis, extended dominance and ethics: A quantitative assessment. Med Decis Making. 1994;14:259-65. [pmid: 7934713].
Carstensen HE, Olsen CE, Sele V, Brorson I, Jensen E, Nissen NI, Fabricius J. [Estrogen therapy of prostatic cancer. 76 cases of previously undiagnosed prostatic cancer treated with F6066 (bis-(p-acetoxyphenyl)cyclohexylidenemethane) and diethylstilbestrol -- a double-blind study]. Nord Med. 1969 Jan 23;81(4):111-4.
Carvalho AP, de Moura JL, Denis L, Newling D, Smith P, Bono A, Sylvester R, De Pauw M, Ongena P. Zoladex and flutamide vs orchidectomy: A phase III EORTC 30853 trial. EORTC Urological Group. Prog Clin Biol Res. 1989;303:129-43. [pmid: 2528736].
Cassileth BR, Soloway MS, Vogelzang NJ, Chou JM, Schellhammer PD, Seidmon EJ, Kennealey GT. Quality of life and psychosocial status in stage D prostate cancer. Zoladex Prostate Cancer Study Group. Qual Life Res. 1992 Oct;1(5):323-29.
Caubet JF, Tosteson TD, Dong EW, Naylon EM, Whiting GW, Ernstoff MS, Ross SD. Maximum androgen blockade in advanced prostate cancer: A meta-analysis of published randomized controlled trials using nonsteroidal antiandrogens. Urology. 1997 Jan;49(1):71-8. [pmcid: 140032].
Cersosimo RJ, Carr D. Prostate cancer: Current and evolving strategies. Am J Health System Pharm. 1996;53(4):381-96. [pmid: 8673658].
Chadwick DJ, Gillatt DA, Gingell JC. Medical or surgical orchidectomy: The patients' choice. BMJ. 1991 Mar 9;302(6776). [pmcid: 318487].
Chalmers TC, Smith H Jr, Blackburn B, Silverman B, Schroeder B, Reitman D, Ambroz A. A method for assessing the quality of a randomized control trial. Controlled Clin Trials. 1981 May;2(1):31-49.
Chang A, Yeap B, Blum R, Hahn R, Khanna O, Fisher H, Witte R, Trump D. A double-blind randomized study of primary treatment for stage D2 prostate cancer: Diethylstilbestrol (DES) vs flutamide(F) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1992;11.
Chang A, Yeap B, Davis T, Blum R, Hahn R, Khanna O, Fisher H, Rosenthal J, Witte R, Schinella R, et al. Double-blind, randomized study of primary hormonal treatment of stage D2 prostate carcinoma: Flutamide versus diethylstilbestrol. J Clin Oncol. 1996 Aug;14(8):2250-7.
Chatelain C, Rousseau V, Cosaert J. French multicentre trial comparing Casodex (ICI 176,334) monotherapy with castration plus nilutamide in metastatic prostate cancer: A preliminary report. Eur Urol. 1994;26(Suppl 1):10-4.
Cheson BD, Kaplan RS, Phillips PH. Clinical trials referral resource. Prostate cancer. Oncology (Huntingt). 1994;8(12):35-6. [pmcid: 419372]. [pmid: 7534101].
Chime-Udeh E. Leuprolide with flutamide for complete androgen ablation: therapeutic alternative for advanced prostatic cancer (stage D2). Conn Med. 1991;55(9):526-8. [pmid: 1748007].
Chodak G, Sharifi R, Kasimis B, Block NL, Macramalla E, Kennealey GT. Single-agent therapy with bicalutamide: A comparison with medical or surgical castration in the treatment of advanced prostate carcinoma. Urology. 1995 Dec;46(6):849-55. [pmcid: 434513].
Chodak GW. Luteinizing hormone-releasing hormone (LHRH) agonists for treatment of advanced prostatic carcinoma. Urology. 1989 May;33(5 Suppl):42-4. [pmid: 2523610].
Chodak GW, Vogelzang NJ, Caplan RJ, Soloway M, Smith JA. Independent prognostic factors in patients with metastatic (stage D2) prostate cancer. The Zoladex Study Group. JAMA. 1991 Feb 6;265(5):618-21.
Chrisp P, Goa KL. Goserelin. A review of its pharmacodynamic and pharmacokinetic properties, and clinical use in sex hormone-related conditions. Drugs. 1991 Feb;41(2):254-88.
Chrisp P, Sorkin EM. Leuprorelin. A review of its pharmacology and therapeutic use in prostatic disorders. Drugs Aging. 1991 Nov;1(6):487-509.
Christensen MM, Aagaard J, Madsen PO. Reasons for delay of endocrine treatment in cancer of the prostate (until symptomatic metastases occur). Prog Clin Biol Res. 1990;359:7-14. [pmid: 2284298].
Cicognani C, Malavolti M, Morselli-Labate AM, Sama C, Barbara L. Flutamide-induced toxic hepatitis. Potential utility of ursodeoxycholicacid administration in toxic hepatitis. Dig Dis Sci. 1996 Nov;41(11):2219-21.
Citrin DL, Resnick MI, Guinan P, al-Bussam N, Scott M, Gau TC, Kennealey GT. A comparison of Zoladex and DES in the treatment of advanced prostate cancer: Results of a randomized, multicenter trial. Prostate. 1991;18(2):139-46. [pmid: 1826048].
Cleary PD, Morrissey G, Oster G. Health-related quality of life in patients with advanced prostate cancer: A multinational perspective. Qual Life Res. 1995 Jun;4(3):207-20.
Coley CM, Barry MJ, Fleming C, Mulley AG. Early detection of prostate cancer. Part 1. Prior probability and effectiveness of tests. Ann Intern Med. 1997a Mar 1;126(5):394-406.
Coley CM, Barry MJ, Fleming C, Fahs MC. Early detection of prostate cancer. Part 2. Estimating the risks, benefits, and costs. Ann Intern Med. 1997b Mar 15;126(6):468-79.
Conn PM, Crowley WF Jr. Gonadotropin-releasing hormone and its analogues. N Engl J Med. 1991 Jan 10;324(2):93-103.
Cookson MS, Sarosdy MF. Hormonal therapy for metastatic prostate cancer: Issues of timing and total androgen ablation. South Med J. 1994 Jan;87(1):1-6.
Cooper HM, Hedges LV, editors. The handbook of research synthesis. New York: The Russell Sage Foundation; 1994.
Corn BW, Hanks GE. Management of stage C (T3) prostate cancer: radiotherapy. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 541-52.
Cowen ME, Chartrand M, Weitzel WF. A Markov model of the natural history of prostate cancer. J Clin Epidemiol. 1994 Jan;47(1):3-21.
Cox RL, Crawford ED. Estrogens in the treatment of prostate cancer. J Urol. 1995 Dec;154(6):1991-8.
Crawford ED. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer [letter]. Urology. 1995 Dec;46(6):899-901. [pmcid: 434513].
Crawford ED. Changing concepts in the management of advanced prostate cancer. Urology. 1994;44(6 Suppl):67-74.
Crawford ED. Combination studies with leuprolide. Eur Urol. 1990a;18(Suppl 3):30-3. [pmid: 2128828].
Crawford ED. Combined androgen blockade. Eur Urol. 1996;29(Suppl 2):54-61. [pmid: 8717465].
Crawford ED. Combined androgen blockade. Urology. 1989;34(4 Suppl):22-6. [pmcid: 434513]. [pmid: 2508291].
Crawford ED. Total androgen blockade: The NCI study [abstract]. In: International Testicular and Prostatic Cancer Conference; 1990b Oct 4-6; Toronto, Canada. p. 91.
Crawford ED, Allen JA. Treatment of newly diagnosed state D2 prostate cancer with leuprolide and flutamide or leuprolide alone, phase III, intergroup study 0036. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):961-3.
Crawford ED, Blumenstein BA, Goodman PJ, Davis MA, Eisenberger MA, McLeod DG, Spaulding JT, Benson R, Dorr FA. Leuprolide with and without flutamide in advanced prostate cancer. Cancer. 1990 Sep 1;66(5 Suppl):1039-44.
Crawford ED, DeAntoni E. Recent American multicenter trials for patients with metastatic prostate cancer [abstract]. In: International Symposium on Recent Advances in Diagnosis and Treatment of Prostate Cancer; 1995 Sep 21-23; Quebec City. p. 30.
Crawford ED, DeAntoni EP, Hussain M, Thompson IM, Coltman CA Jr. Prostate cancer clinical trials of the Southwest Oncology Group. Oncology (Huntingt). 1997 Aug;11(8):1154-63. [pmcid: 419372].
Crawford ED, DeAntoni EP. Current status of combined androgen blockade: optimal therapy for advanced prostate cancer. J Clin Endocrinol Metab. 1995 Apr;80(4):1062-76.
Crawford ED, Eisenberger MA, McLeod DG, Spaulding JT, Benson R, Dorr FA, Blumenstein BA, Davis MA, Goodman PJ. A controlled trial of leuprolide with and without flutamide in prostatic carcinoma. N Engl J Med. 1989 Aug 17;321(7):419-24.
Crawford ED, Fourcade RO, Iversen P, et al. Management of newly diagnosed, metastatic prostate cancer. In: Murphy G, Griffiths K, Denis L, et al., editors. First International Consultation on Prostate Cancer. London: Scientific Communication International, Ltd; 1997. p. 267-303.
Crawford ED, Goodman P, Blumenstein B. Combined androgen blockade: Leuprolide and flutamide versus leuprolide and placebo. Semin Urol. 1990 Aug;8(3):154-8.
Crawford ED, Hussain M, DeAntoni EP, Thompson IM, Eisenberger MA, Blumenstein B, Coltman CA Jr. Southwest Oncology Group strategies in prostatic carcinoma. Semin Surg Oncol. 1995 Jan;11(1):60-4.
Crawford ED, Kasimis BS, Gandara D, Smith JA, Soloway MS, Lange PH, Lynch DF, Al-Juburi A, Bracken RB, Wise HA, et al. A randomized, controlled clinical trial of leuprolide and anandron (LA) vs leuprolide and placebo (LP) for advanced prostate cancer (D2cap) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1990;9.
Crawford ED, Nabors WL. Total androgen ablation: American experience. Urol Clin North Am. 1991 Feb;18(1):55-63.
Creaven PJ, Pendyala L, Tremblay D. Pharmacokinetics and metabolism of nilutamide. Urology. 1991;37(2 Suppl):13-9.
Cresswell SM, English PJ, Hall RR, Roberts JT, Marsh MM. Pain relief and quality-of-life assessment following intravenous and oral clodronate in hormone-escaped metastatic prostate cancer. Br J Urol. 1995;76(3):360-5. [pmid: 7551847].
da Silva FC. Quality of life in prostatic cancer patients. Cancer. 1993 Dec 15;72(12 Suppl):3803-6. [pmid: 8252494].
da Silva FC. Quality of life in prostatic carcinoma. Eur Urol. 1993;24(Suppl 2):113-7. [pmid: 8262115].
da Silva FC, Aaronson N. Quality of life assessment in prostatic cancer. Prog Clin Biol Res. 1988;260:119-21. [pmid: 2966404].
da Silva FC, Fossa SD, Aaronson NK, Serbouti S, Denis L, Casselman J, Whelan P, Hetherington J, Fava C, Richards B, et al. The quality of life of patients with newly diagnosed M1 prostate cancer: Experience with EORTC clinical trial 30853. Eur J Cancer. 1996 Jan;32A(1):72-7.
da Silva FC, Reis E, Costa T, Denis L. Quality of life in patients with prostatic cancer. A feasibility study. The Members of Quality of Life Committee of the EORTC Genitourinary Group. Cancer. 1993 Feb 1;71(3 Suppl):1138-42.
Dalesio O. Complete androgen blockade in prostate cancer. Organizing an overview. Cancer. 1990 Sep 1;66(5 Suppl):1080-2. [pmid: 2203518].
Dalesio O. Complete androgen blockade in prostate cancer: an overview of randomized trials. Prostate Suppl. 1992;4:111-4. [pmid: 1533451].
Daniell HW. Osteoporosis after orchiectomy for prostate cancer. J Urol. 1997 Feb;157(2):439-44. [pmid: 8996327].
Daponte DP, Stevens I, Robinson MR. [Plasma changes caused by estrogens in the vascular risk of prostatic carcinoma over a 3-year period]. Actas Urol Esp. 1986 Nov-Dec;10(6):437-40.
De Coster R, Wouters W, Bruynseels J. P450-dependent enzymes as targets for prostate cancer therapy. J Steroid Biochem Mol Biol. 1996 Jan;56(1-6 Spec No):133-43.
De Sy WA, De Meyer JM, Casselman J, De Smet R, Renders G, Schelfhout W, De Wilde P. A comparative study of a long acting luteinizing hormone releasing hormone agonist (Decapeptyl) and orchiectomy in the treatment of advanced prostatic cancer. Preliminary report. Acta Urol Belg. 1986;54(2):221-9. [pmid: 2942015].
De Sy WA, De Wilde P, De Meyer JM, Casselman J, Desmet R, Renders G, Schelfhout W. Long term experience in the treatment of advanced prostatic cancer with decapeptyl, compared to orchiectomy. Acta Urol Belg. 1988;56(4):581-8. [pmid: 2974680].
de Voogt HJ. Comparative studies with LHRH-agonists. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:309-14.
de Voogt HJ. Cyproterone acetate as monotherapy in prospective randomized trials. Prog Clin Biol Res. 1990;359:85-91. [pmid: 2149459].
de Voogt HJ. [Prostate cancer; hormonal treatment in a new stage?]. Ned Tijdschr Geneeskd. 1986 Apr 26;130(17):766-8. [pmid: 2423887].
de Voogt HJ, Klijn JG, Studer U, Schroder F, Sylvester R, De Pauw M. Orchidectomy versus Buserelin in combination with cyproterone acetate, for 2 weeks or continuously, in the treatment of metastatic prostatic cancer. Preliminary results of EORTC-trial 30843. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):965-9.
de Voogt HJ, Pavone-Macaluso M, Smith PH, de Pauw M, Suciu S. Lessons from phase III-trials on the hormonal treatment of prostatic cancer. I: Results of EORTC-trials 30761 and 30762. Prog Clin Biol Res. 1988;260:111-7. [pmid: 2966403].
de Voogt HJ, Pavone-Macaluso M, Sylvester R, Schroder FH. Re: Cardiovascular side effects of diethylstilbestrol, cyproterone acetate, medroxyprogesterone acetate and estramustine phosphate used for the treatment of advanced prostatic cancer: Results from European Organization for Research on Treatment of Cancer Trials 30761 and 30762 [letter]. J Urol. 1988 Dec;140(6).
de Voogt HJ, Smith PH, Pavone-Macaluso M, de Pauw M, Suciu S. Cardiovascular side effects of diethylstilbestrol, cyproterone acetate, medroxyprogesterone acetate and estramustine phosphate used for the treatment of advanced prostatic cancer: Results from European Organization for Research on Treatment of Cancer trials 30761 and 30762. J Urol. 1986 Feb;135(2):303-7.
de Voogt HJ, Suciu S, Sylvester R, Pavone-Macaluso M, Smith PH, de Pauw M. Multivariate analysis of prognostic factors in patients with advanced prostatic cancer: Results from 2 European Organization for Research on Treatment of Cancer trials. J Urol. 1989 Apr;141(4):883-8.
DeAntoni E, Crawford ED. [Recent multicenter study protocols in the USA for patients with metastatic prostatic carcinoma]. Urologe A. 1995 Sep;34(5):382-8.
DeAntoni EP, Crawford ED. Pretreatment of metastatic disease. Prostate cancer in the older male. Cancer. 1994 Oct 1;74(7 Suppl):2182-7.
Debruyne FM. Combined androgen blockade is the treatment of choice for patients with advanced prostate cancer: The argument for. Eur Urol. 1996;29(Suppl 2):34-6. [pmid: 8717460].
Debruyne FM. Results of a Dutch trial with the LHRH agonist buserelin in patients with metastatic prostatic cancer and results of EORTC studies in prostatic cancer. Am J Clin Oncol. 1988;11(Suppl 1):S33-S35. [pmid: 2968760].
Debruyne FM, Dijkman GA. Advances and trends in hormonal therapy for advanced prostate cancer. Eur Urol. 1995;28(3):177-88. [pmid: 8536770].
Debruyne FM, Dijkman GA, Lee DC, Witjes WP, del Moral F, Karthaus HF, van der Mejden AP, Plasman JW, Pull HC, Kums JJ et al. A new long acting formulation of the luteinizing hormone-releasing hormone analogue goserelin: results of studies in prostate cancer. J Urol. 1996 Apr;155(4):1352-4.
Debruyne FM, Fernandez del Moral P, Geboers AD. LHRH-analogues therapy for metastatic prostate cancer. Prog Clin Biol Res. 1988;260:27-39. [pmid: 2966406].
Decensi A, Guarneri D, Paoletti MC, Lalanne JM, Merlo F, Boccardo F. Phase II study of the pure non-steroidal antiandrogen nilutamide in prostatic cancer. Italian Prostatic Cancer Project (PONCAP). Eur J Cancer. 1991;27(9):1100-4. [pmid: 1835617].
Decensi A, Torrisi R, Fontana V, Marroni P, Padovani P, Guarneri D, Minuto F, Boccardo F. Long-term endocrine effects of administration of either a non-steroid antiandrogen or a luteinizing hormone-releasing hormone agonist in menwith prostate cancer. Acta Endocrinol. 1993;129(4):315-21. [pmid: 8237249].
Decensi A, Torrisi R, Marroni P, Pensa F, Padovani P, Boccardo F. Effect of the nonsteroidal antiandrogen nilutamide on adrenal androgen secretion. Prostate. 1994;24(1):17-23. [pmid: 8290386].
Fernandez del Moral P, Dijkman GA, Debruyne FMJ, Witjes WPJ, Kolvenbag GJCM,. Three-month depot of goserelin acetate: Clinical efficacy and endocrine profile. [Dutch South East Cooperative Urological Group. Urology. 1996;48(6):894-900. [pmcid: 140032]. [pmid: 8973673].
Dempster AD, Laird NM, Rubin DB. Maximum likelihood from incomplete data via the EM algorithm. J Royal Stat Soc B. 1977;38:1-22.
Denis L. A new non-steroidal anti-androgen. Prog Clin Biol Res. 1989;303:95-103. [pmid: 2675023].
Denis L. Commentary on maximal androgen blockade in prostate cancer: A theory to put into practice?. Prostate. 1995 Nov;27(5):233-40. [pmid: 7479390].
Denis L. Prostate cancer. Primary hormonal treatment. Cancer. 1993 Feb 1;71(3 Suppl):1050-8. [pmid: 8428327].
Denis L. Role of combination therapy in advanced prostatic cancer [abstract]. In: International Symposium on Recent Advances in Diagnosis and Treatment of Prostate Cancer; 1995 Sep 21-23; Quebec City.p. 32.
Denis L. Role of maximal androgen blockade in advanced prostate cancer. Prostate Suppl. 1994;5:17-22. [pmid: 8172710].
Denis L, Dalesio O, Murphy G. [Review of phase III clinical trials on combined anti-androgen therapies in patients with metastasized prostatic cancer]. Prog Urol. 1993 Feb;3(1):75-85.
Denis L, Keuppens F, Newling D, Smith P H, Calais da Silva F, Sylvester R, DePauw M, Onegana P and Members of the EORTC-GU Group Belgium. Orchidectomy versus total androgen blockade: A phase III EORTC 30853 study. GnRH Analogues Cancer Human Reproduction. 1990;3:117-27.
Denis L, Keuppens F, Robinson M, Mahler C, Smith P, Pinto de Carvalho AP, Newling D, Bono A, Sylvester R, De Pauw M, et al. Complete androgen blockade: Data from an EORTC 30853 trial. Semin Urol. 1990 Aug;8(3):166-74.
Denis L, Mettlin C. Combined castration and androgen blockade therapy in prostate cancer. Conclusions. Cancer. 1990 Sep 1;66(5 Suppl):1086-9.
Denis L, Murphy GP. Overview of phase III trials on combined androgen treatment in patients with metastatic prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3888-95.
Denis L, Robinson M, Mahler C, Smith P, Keuppens F, De Moura JL, Bono A, Newling D, Sylvester R, De Pauw M, et al. Orchidectomy versus Zoladex plus Eulexin in patients with metastatic prostate cancer (EORTC 30853). J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):951-9.
Denis L, Smith P, Carneiro de Moura JL, Newling D, Bono A, Keuppens F, Mahler C, Robinson M, Sylvester R, De Pauw M, et al. Total androgen ablation: European experience. The EORTC GU Group. Urol Clin North Am. 1991 Feb;18(1):65-73.
Denis L, Smith PH, De Moura JL, Newling DW, Bono A, Keuppens F, Robinson M, Mahler C, Sylvester R, De Pauw M, et al. Orchidectomy vs. Zoladex plus flutamide in patients with metastatic prostate cancer. The EORTC GU Group. Eur Urol. 1990;18(Suppl 3):34-40. [pmid: 2151274].
Denis LJ, Carneiro de Moura JL, Bono A, Sylvester R, Whelan P, Newling D, Depauw M. Goserelin acetate and flutamide versus bilateral orchiectomy: A phase III EORTC trial (30853). EORTC GU Group and EORTC Data Center. Urology. 1993 Aug;42(2):119-29. [pmcid: 434513].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
Di Silverio F, Sciarra F, D'Eramo G. Advanced prostatic cancer: Clinical and hormonal response to flutamide in patients pretreated with LHRH analogue and cyproterone acetate. Eur Urol. 1990;18(1):10-5.
Di Silverio F, Serio M, D'Eramo G, Sciarra F. Zoladex vs. Zoladex plus cyproterone acetate in the treatment of advanced prostatic cancer: A multicenter Italian study. Eur Urol. 1990;18(Suppl 3):54-61. [pmid: 2151278].
Di Silverio F, Serio M. [Zoladex in prostatic carcinoma]. Drugs Exp Clin Res. 1990;16(Suppl):19-29. [pmid: 2150501].
Dijkman GA, Debruyne F , Fernandez del Moral P, Plasman JW, Hoefakker JW, Idema JG, Sykes M. A randomised trial comparing the safety and efficacy of the Zoladex 10.8-mg depot, administered every 12 weeks, to that of the Zoladex 3.6-mg depot, administered every 4 weeks, in patients with advanced prostate cancer. The Dutch South East Cooperative Urological Group. Eur Urol. 1995;27(1):43-6. [pmid: 7744141].
Dijkman GA, Debruyne FM, Fernandez del Moral P, Plasman J W, Hoefakker J W, Idema J G, Sykes M. A phase III randomized trial comparing the efficacy and safety of the 3-monthly 10.8-mg depot of Zoladex with the monthly 3.6-mg depot in patients with advanced prostate cancer. Dutch South East Cooperative Urological Group. Eur Urol. 1994;26 (Suppl 1):1-2.
Dijkman GA, Fernandez del Moral P, Debruyne FM, Janknegt RA. Improved subjective responses to orchiectomy plus nilutamide (anandron) in comparison to orchiectomy plus placebo in metastatic prostate cancer. International Anandron Study Group. Eur Urol. 1995;27(3):196-201. [pmid: 7601182].
Dijkman GA, Janknegt RA, De Reijke TM, Debruyne FM. Long-term efficacy and safety of nilutamide plus castration in advanced prostate cancer, and the significance of early prostate specific antigen normalization. International Anandron Study Group. J Urol. 1997 Jul;158(1):160-3.
Drug Topics Red Book. Montvale, NJ: Medical Economics; 1997.
Du Plessis DJ. Castration plus nilutamide vs castration plus placebo in advanced prostate cancer. A review. Urology. 1991;37(2 Suppl):20-4. [pmid: 1992599].
Einstein AB Jr. Hormonal therapy for locally advanced prostate cancer. In: Management of Clinically Localized Prostate Cancer. NIH Consensus Development Conference. NCI Mongr;1987; Bethesda, MD: National Institutes of Health, 1988. p. 171-4.
Einstein AB Jr. Hormonal therapy for prostate cancer-when to use it. Cancer Control. 1995;2(1):32-36. [pmid: 10887394].
Eisenberger M, Abrams J. Gonadotropin hormone-releasing hormone analogs for the treatment of prostatic cancer. Drugs Today. 1988;24(4):241-8.
Eisenberger M, Crawford ED, McCleod D, Benson R, Dorr A, Blumenstein B. A comparison of leuprolide and flutamide vs leuprolide alone in newly diagnosed stage D2 prostate cancer: Prognostic and therapeutic importance of the minimal disease subset [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1992;11.
Eisenberger M, Crawford ED, McLeod D, Hussain M, Loehrer P, Blumenstein B. The prognostic significance of prostate specific antigen (PSA) in stage D2 prostate cancer (PC) interim evaluation of Intergroup Study 0105 [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Eisenberger M, Crawford ED, McLeod D, Loehrer P, Wilding G, Blumenstein B. A comparison of bilateral orchiectomy (orch) with or without flutamide in stage D2 prostate cancer (PC) (NCI INT-0105 SWOG/ECOG) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1997;16.
Eisenberger MA, Blumenstein BA, Crawford ED, Miller G, McLeod DG, Loehrer PJ, Wilding G, Sears K, Culkin DJ, Thompson IM Jr, et al. Bilateral orchiectomy with or without flutamide for [metastatic] prostate cancer. N Engl J Med. 1998;339(15):1036-42. [pmid: 9761805].
Eisenberger MA, Crawford ED, Wolf M, Blumenstein B, McLeod DG, Benson R, Dorr FA, Benson M, Spaulding JT. Prognostic factors in stage D2 prostate cancer; important implications for future trials: Results of a Cooperative Intergroup Study (Int.0036). The National Cancer Institute Intergroup Study #0036. Semin Oncol. 1994;21(5):613-9. [pmid: 7939752].
Ellis WJ, Lange PH. Prostate cancer. Endocrinol Metab Clin North Am. 1994 Dec;23(4):809-24.
Emtage LA, George J, Boughton BJ, Trethowan C, Blackledge GR. Haemostatic changes during hormone manipulation in advanced prostate cancer: a comparison of DES 3 mg/day and goserelin 3.6 mg/month. Eur J Cancer. 1990 Mar;26(3):315-9.
Emtage LA, Lewis PW, Blackledge GR. The role of prostate specific antigen in the baseline assessment of patients undergoing hormone therapy for advanced prostate cancer. Br J Urol. 1987 Dec;60(6):572-7.
Emtage LA, Trethowan C, Hilton C, Kelly K, Blackledge GR. Interim report of a randomized trial comparing Zoladex 3.6 mg depot with diethylstilbestrol 3 mg/day in advanced prostate cancer. The West Midlands Urology Research Group. Am J Clin Oncol. 1988;11(Suppl 2):S173-S175. [pmid: 2977273].
Emtage LA, Trethowan C, Kelly K, Arkell D, Wallace DM, Hughes M, Hay A, Blacklock R, Jones M, Rouse A, et al. A phase III open randomized study of Zoladex 3.6 mg depot vs. DES 3 mg per day in untreated advanced prostate cancer: A West Midlands Urological Research Group Study. Prog Clin Biol Res. 1989;303:47-52. [pmid: 2528739].
Epstein JI, Walsh PC, Brendler CB. Radical prostatectomy for impalpable prostate cancer: The Johns Hopkins experience with tumours found on transurethral resection (stages T1A and T1B) and on needle biopsy. J Urol. 1994 Nov;152(5 Pt 2):1721-9.
Eriksson A, Carlstrom K. Prognostic value of serum hormone concentrations in prostatic cancer. Prostate. 1988;13(3):249-56. [pmid: 3211806].
European Organization for Research and Treatment of Cancer (EORTC). Practical Guidelines for Clinical Studies. Brussels: European Organization for Research and Treatment of Cancer; 1996.
Everson RB, Byar DP, Bischoff AJ. Estrogen predisposes to cholecystectomy but not to stones. Gastroenterology. 1982 Jan;82(1):4-8. [pmcid: 194733].
Faraggi D, Simon R. A neural network model for survival data. Stat Med. 1995;14(1):73-82. [pmid: 7701159].
Faul P, Altwein JE. [Advanced prostatic cancer: therapeutic modalities]. Dtsch Med Wochenschr. 1984;109(51-52):1975-80. [pmid: 6391887].
Ferrari P, Castagnetti G, Ferrari G, Baisi B, Dotti A. Combination treatment versus LHRH alone in advanced prostatic cancer. Urol Int. 1996;56(Suppl 1):13-7.
Ferrari P, Castagnetti G, Ferrari G, Pollastri CA, Tavoni F, Dotti A. Combination treatment in M1 prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3880-5.
Fiet J, Dore J C, Go A L, Ojasoo T, Raynaud J P. Multivariate analysis of plasma hormones in patients with metastatic prostate cancer receiving combined LHRH-analog and antiandrogen therapy. Prostate. 1993;23(4):291-313. [pmid: 8259343].
Filicori M. Gonadotrophin-releasing hormone agonists. A guide to use and selection. Drugs. 1994;48(1):41-58. [pmid: 7525194].
Fitzpatrick JM. Combined androgen blockade is the treatment of choice for patients with advanced prostate cancer: the argument against. Eur Urol. 1996;29(Suppl 2):37-9. [pmid: 8717461].
Fleming C, Wasson JH, Albertsen PC, Barry MJ, Wennberg JE. A decision analysis of alternative treatment strategies for clinically localized prostate cancer. Prostate Patient Outcomes Research Team. JAMA. 1993 May 26;269(20):2650-8.
Foote JE, Crawford ED. Total androgen suppression: Are there any advantages? The use of combined therapy in the treatment of advanced prostate adenocarcinoma. Semin Urol. 1988 Nov;6(4):291-302.
Fornara P, Jocham D. Clinical study results of the new formulation leuprorelin acetate three-month depot for the treatment of advanced prostate carcinoma. Urol Int. 1996;56 (Suppl 1):18-22. [pmid: 8776813].
Forti G. Clinical applications of GNRH analogs. J Endocrinol Invest. 1988;11(10):745-54. [pmid: 3068292].
Forti G, Selli C. Prospects for prostatic cancer incidence and treatment by the year 2000. Int J Androl. 1996;19(1):1-10.
Fossa SD. Quality of life in advanced prostate cancer. Semin Oncol. 1996;23(6 Suppl 14):32-4. [pmid: 8996583].
Fourcade RO, Cariou G, Coloby P, Colombel P, Coulange C, Grise P, Mangin P, Soret JY, Poterre M. Total androgen blockade with Zoladex plus flutamide vs. Zoladex alone in advanced prostatic carcinoma: Interim report of a multicenter, double-blind, placebo-controlled study. Eur Urol. 1990;18(Suppl 3):45-7.
Frazier HA, Robertson JE, Humphrey PA, Paulson DF. Is prostate specific antigen of clinical importance in evaluating outcome after radical prostatectomy. J Urol. 1993 Mar;149(3):516-8.
Frydenberg M, Oesterling JE. Management of stage C (T3) prostate cancer: nonradiation therapy. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 535-41.
Furr BJ. Casodex: Preclinical studies and controversies. Ann NY Acad Sci. 1995 Jun 12;761:79-96. [pmid: 7625752].
Furr BJ. Relative potencies of flutamide and 'Casodex.'. Endocrine Rel Cancer. 1997;4(2):197-202.
Gaillard-Moguilewsky M. Pharmacology of antiandrogens and value of combining androgen suppression with antiandrogen therapy. Urology. 1991;37(2 Suppl):5-12. [pmid: 1992602].
Gann PH, Hennekens CH, Stampfer MJ. A prospective evaluation of plasma prostate-specific antigen for detection of prostatic cancer. JAMA. 1995 Jan 25;273(4):289-94.
Garnick MB. Hormonal therapy in the management of prostate cancer: From Huggins to the present. Urology. 1997 Mar;49(Suppl 3A):5-15. [pmcid: 140032]. [pmid: 9123737].
Garnick MB. Leuprolide versus diethylstilbestrol for previously untreated stage D2 prostate cancer. Results of a prospectively randomized trial. Urology. 1986 Jan;27(1 Suppl):21-8. [pmid: 3079935].
Garnick MB. Prostate cancer: Screening, diagnosis, and management. Ann Intern Med. 1993 May 15;118(10):804-18. [pmid: 7682387].
Garnick MB, Glode LM, Smith JA Jr, Max DT. Leuprolide: A review of its effects in comparison with diethylstilboestrol in the treatment of advanced cancer of the prostate. Br J Clin Pract. 1985a Feb;39(2):73-6.
Garnick MB, Glode LM, Smith JA Jr, Max DT. Leuprolide: A review of its effects in comparison with diethylstilboestrol in the treatment of advanced cancer of the prostate. Br J Clin Pract Symp Suppl. 1985b Mar;37:8-12, 20-4. [pmid: 3931665].
Gee WF, Holtgrewe HL, Albertsen PC, Litwin MS, Manyak MJ, O'Leary MP, Painter MR. Practice trends in the diagnosis and management of prostate cancer in the United States. J Urol. 1995 Jul;154(1):207-8.
Geller J, Albert J, Vik A. Advantages of total androgen blockade in the treatment of advanced prostate cancer. Semin Oncol. 1988 Apr;15(2 Suppl 1):53-61.
Geller J. Basis for hormonal management of advanced prostate cancer. Cancer. 1993 Feb 1;71(3 suppl):1039-45. [pmid: 7679038].
Gibbs SJ, Plowman PN. Androgen deprivation and antagonism in the treatment of advanced prostatic carcinoma. Clin Oncol (R Coll Radiol). 1996;8(6):346-52. [pmid: 8973848].
Giuliani L, Pescatore D, Giberti C, Martorana G, Natta G. Treatment of advanced prostatic carcinoma with cyproterone acetate and orchiectomy -- 5-year follow-up. Eur Urol. 1980;6(3):145-8. [pmid: 7371659].
Goethuys H, Baert L, Van Poppel H, Lieskovsky G, Brady LW, Petrovich Z. Treatment of metastatic carcinoma of the prostate. Am J Clin Oncol. 1997;20(1):40-5. [pmid: 9020286].
Gold MR, Seigel JE, Russell LB, et al., editors. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Goldenberg SL, Bruchovsky N. Androgen withdrawal therapy: New perspectives in the treatment of prostate cancer. In: Rhagavan D, Scher RI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 583-91.
Goldenberg SL, Bruchovsky N. Use of cyproterone acetate in prostate cancer. Urol Clin North Am. 1991 Feb;18(1):111-22.
Goldenberg SL, Bruchovsky N, Gleave ME, Sullivan LD, Akakura K. Intermittent androgen suppression in the treatment of prostate cancer: A preliminary report. Urology. 1995 May;45(5):839-44.
Goldenberg SL, Bruchovsky N, Rennie PS, Coppin CM, Brown EM. The use of synergistic hormonal combinations in the treatment of advanced prostatic cancer: Cyproterone acetate plus mini-dose diethylstilbestrol. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:127-33.
Goldspiel BR, Kohler DR. Flutamide: An antiandrogen for advanced prostate cancer. DICP. 1990 Jun;24(6):616-23.
Granfors T, Modig H, Damber J-E, Tomic R. Combined orchiectomy and external radiotherapy versus radiotherapy alone for nonmetastatic prostate cancer with or without pelvic lymph node involvement: A prospective randomized study. J Urol. 1998 Jun;159(6):2030-4.
Griffiths K. Is there a best castration?. Cancer. 1993 Dec 15;72(12 Suppl):3807-9. [pmid: 8252495].
Grossman HB. Hormonal therapy of prostatic carcinoma: is there a rationale for delayed treatment?. Urology. 1986 Mar;27(3):199-204. [pmid: 3513424].
Haapiainen R, Rannikko S, Adlercreutz H, Alfthan O. Correlation of pretreatment plasma levels of estradiol and sex-hormone-binding globulin-binding capacity with clinical stage and survival of patients with prostatic cancer. Prostate. 1986;8(2):127-37. [pmid: 3952023].
Haapiainen R, Rannikko S, Alfthan O, Adlercreutz H. Pretreatment plasma levels of testosterone and sex hormone binding globulin binding capacity in relation to clinical staging and survival in prostatic cancer patients. Prostate. 1988;12(4):325-32. [pmid: 3393494].
Haefliger JM. [Randomized study comparing zoladex versus zoladex plus flutamide in treatment of advanced cancer of the prostate]. Helv Chir Acta. 1992 Oct;59(3):477-83. [pmid: 1464545].
Hasselblad V. Meta-analysis of multitreatment studies. Med Decision Making. 1998 Jan;18(1):37-43.
Hasselblad V. Numerical techniques in distribution fitting. Comp Sci Stat. 1994;26:217-21.
Hedges LV, Olkin I, editors. Statistical methods for meta-analysis. Orlando: Academic Press; 1985.
Henriksson P. Estrogen in patients with prostatic cancer. An assessment of the risks and benefits. Drug Saf. 1991 Jan;6(1):47-53. [pmid: 2029353].
Henriksson P, Blomback M, Bratt G, Edhag O, Eriksson A, Vesterqvist O. Effects of oestrogen therapy and orchidectomy on coagulation and prostanoid synthesis in patients with prostatic cancer. Med Oncol Tumor Pharmacother. 1989;6(3):219-25. [pmid: 2515399].
Henriksson P, Blomback M, Bratt G, Edhag O, Eriksson A. Activators and inhibitors of coagulation and fibrinolysis in patients with prostatic cancer treated with oestrogen or orchidectomy. Thromb Res. 1986;44(6):783-91. [pmid: 3798420].
Henriksson P, Edhag O. Orchidectomy versus oestrogen for prostatic cancer: Cardiovascular effects. Br Med J (Clin Res Ed). 1986 Aug 16;293(6544):413-5.
Henriksson P, Edhag O, Eriksson A, Johansson SE. Patients at high risk of cardiovascular complications in oestrogen treatment of prostatic cancer. Br J Urol. 1989 Feb;63(2):186-90.
Henriksson P, Einarsson K, Eriksson A, Kelter U, Angelin B. Estrogen-induced gallstone formation in males. Relation to changes in serum and biliary lipids during hormonal treatment of prostatic carcinoma. J Clin Invest. 1989;84(3):811-6. [pmcid: 303697]. [pmid: 2760214].
Henriksson P, Johansson SE. Prediction of cardiovascular complications in patients with prostatic cancer treated with estrogen. Am J Epidemiol. 1987;125(6):970-8. [pmid: 3578255].
Henriksson P, Stege R. Cost comparison of parenteral estrogen and conventional hormonal treatment in patients with prostatic cancer. Int J Technol Assess Health Care. 1991;7(2):220-5. [pmid: 1907600].
Herbst WP. Biochemical therapeusis in carcinoma of the prostate gland: Preliminary report. JAMA. 1942;120:1116-20.
Herbst WP. Effects of estradiol dipropionate and diethyl stilbestrol on malignant prostatic tissue. Trans Am Assoc Genitourin Surg. 1941;34:195-202.
Hermabessiere J. [Cyproterone acetate: cardiovascular tolerance]. Prog Urol. 1992 Apr;2(2):226-33. [pmid: 1302058].
Herr H, Kornblith AB, Ofman U. A comparison of the quality of life of patients with metastatic prostate cancer who received or did not receive hormonal therapy. Cancer. 1993 Feb 1;71(3 Suppl):1143-50.
Hillner BE, McLeod DG, Crawford ED, Bennett CL. Estimating the cost effectiveness of total androgen bockade with flutamide in M1 prostate cancer. Urology. 1995 Apr;45(4):633-40.
Hinotsu S, Ohasi Y, Akaza H. [An overview of clinical trials in endocrine therapy for cancer. ]. Jpn J Cancer Chemother. 1996;23(6):689-694.
Hoechst Marion Roussel, Inc. Nilandron® (nilutamide) tablet prescribing information. Kansas City, MO; 1996 Sep.
Hoisaeter PA, Rasmussen F. The Scandinavian Prostatic Cancer Group. Scand J Clin Lab Invest Suppl. 1985;179:7-11. [pmid: 2934797].
Hollander V. Prostate cancer: Clinical trials of gonadotrophin-releasing hormone analogs as an alternative to orchiectomy. Mt Sinai J Med. 1985 Mar;52(3):205-6. [pmid: 3921828].
Holtgrewe HL, Bay-Nielsen H, Bouffioux C, et al. The economics of prostate cancer. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 399-414.
Hsieh WS, Simons JW. Systemic therapy of prostate cancer. New concepts from prostate cancer tumor biology. Cancer Treat Rev. 1993 Jul;19(3):229-60.
Huben RP, Murphy GP. A comparison of diethylstilbestrol or orchiectomy with buserelin and with methotrexate plus diethylstilbestrol or orchiectomy in newly diagnosed patients with clinical stage D2 cancer of the prostate. Cancer. 1988 Nov 1;62(9):1881-7.
Huben RP, Perrapato SD. Drug therapy of prostatic cancer. Drugs Aging. 1991 Sep;1(5):353-63.
Hucher M, de Gery A, Bertagna C. Anandron (nilutamide) combined with orchiectomy in stage D prostate cancer patients. Overview of seven randomized placebo controlled studies. Cancer. 1993 Dec 15;72(12 Suppl):3886-7.
Huggins C, Hodges CV. Studies on prostate cancer. 1. The effects of castration, of estrogen and of androgen injection on serum phosphatases in metastatic carcinoma of the prostate. Cancer Res. 1941;1:293-7.
Huggins C, Scott WW. Bilateral adrenalectomy in prostate cancer. Ann Surg. 1945;122:1031-41.
Huggins C, Stevens RE, Hodges CV. Studies on prostatic cancer, II: The effects of castration on advanced carcinoma of the prostate gland. Arch Surg. 1941;43:209-23. [pmcid: 28483].
Hurst KS, Byar DP. An analysis of the effects of changes from the assigned treatment in a clinical trial of treatment for prostatic cancer. J Chronic Dis. 1973 May;26(5):311-24.
Hussain MH, Blumenstein B, Eisenberger M, Crawford ED. Southwest Oncology Group studies in hormone-refractory prostate cancer. Semin Oncol. 1996;23(6 Suppl 14):24-7.
Hussain MH, Crawford ED. Androgen deprivation strategies for metastatic prostate cancer. In: Rhagavan D, Scher RI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 591-7.
Iversen P. Combined androgen blockade in the treatment of advanced prostate cancer-an overview. The Scandinavian Prostatic Cancer Group. Scand J Urol Nephrol. 1997 Jun;31(3):249-54. [pmid: 9249887].
Iversen P. Update of monotherapy trials with the new anti-androgen, Casodex (ICI 176,334). International Casodex Investigators. Eur Urol. 1994;26 (Suppl 1):5-9. [pmid: 7737258].
Iversen P. Zoladex plus flutamide vs. orchidectomy for advanced prostatic cancer. Danish Prostatic Cancer Group (DAPROCA). Eur Urol. 1990;18(Suppl 3):41-4. [pmid: 2151275].
Iversen P, Christensen MG, Friis E, Hornbol P, Hvidt V, Iversen HG, Klarskov P, Krarup T, Lund F, Mogensen P, et al. A phase III trial of zoladex and flutamide versus orchiectomy in the treatment of patients with advanced carcinoma of the prostate. Cancer. 1990 Sep 1;66(5 Suppl):1058-66.
Iversen P, Rasmussen F, Klarskov P, Christensen IJ. Long-term results of Danish Prostatic Cancer Group trial 86. Goserelin acetate plus flutamide versus orchiectomy in advanced prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3851-4.
Iversen P, Shipley WU, Newling DW, Kurth DL. Panel discussion I. Prostate. 1994;24(Suppl 5):15-6.
Iversen P, Suciu S, Sylvester R, Christensen I, Denis L. Zoladex and flutamide versus orchiectomy in the treatment of advanced prostatic cancer. A combined analysis of two European studies, EORTC 30853 and DAPROCA 86. Cancer. 1990;66(5 Suppl):1067-73. [pmid: 2144208].
Iversen P, Tveter K, Varenhorst E. Randomised study of Casodex 50 MG monotherapy vs orchidectomy in the treatment of metastatic prostate cancer. The Scandinavian Casodex Cooperative Group. Scand J Urol Nephrol. 1996 Apr;30(2):93-8.
Iversen P, Tyrrell CJ, Kaisary AV, Anderson JB, Baert L, Tammela T, Chamberlain M, Carroll K, Gotting-Smith K, Blackledge GR. Casodex (bicalutamide) 150-mg monotherapy compared with castration in patients with previously untreated nonmetastatic prostate cancer: Results from two multicenter randomized trials at a median follow-up of 4 years. Urology. 1998 Mar;51(3):389-96.
Jacobi GH, Wenderoth UK, Ehrenthal W, von Wallenberg H, Spindler HW, Hohenfellner R. Endocrine and clinical evaluation of 107 patients with advanced prostatic carcinoma under long-term pernasal buserelin or intramuscular decapeptyl depot treatment. Am J Clin Oncol. 1988;11(Suppl 1):S36-S43. [pmid: 2968761].
Jacobo E, Schmidt JD, Weinstein SH, Flocks RH. Comparison of flutamide (SCH-13521) and diethylstilbestrol in untreated advanced prostatic cancer. Urology. 1976 Sep;8(3):231-3. [pmcid: 126229].
Jacobsen SJ, Katusic SK, Bergstralh EJ, Oesterling JE, Ohrt D, Klee GG, Chute CG, Lieber MM. Incidence of prostate cancer diagnosis in the eras before and after serum prostate-specific antigen testing. JAMA. 1995 Nov 8;274(18):1445-9.
Janknegt RA. Total androgen blockade with the use of orchiectomy and nilutamide (Anandron) or placebo as treatment of metastatic prostate cancer. Anandron International Study Group. Cancer. 1993 Dec 15;72(12 Suppl):3874-7. [pmid: 8252507].
Janknegt RA, Abbou CC, Bartoletti R, Bernstein-Hahn L, Bracken B, Brisset JM, Da Silva FC, Chisholm G, Crawford ED, Debruyne FM, et al. Orchiectomy and nilutamide or placebo as treatment of metastatic prostatic cancer in a multinational double-blind randomized trial. J Urol. 1993 Jan;149(1):77-82.
Javadpour N. Selected advances in therapy of urologic cancer-luteinizing hormone releasing hormone (LHRH) and biologic response modifier (BUR). Prog Clin Biol Res. 1988;277:27-38. [pmid: 2973069].
Jewett HJ. The present status of radical prostatectomy for stages A and B prostatic cancer. Urol Clin North Am. 1975 Feb;2(1):105-24. [pmid: 1128746].
Johansson JE, Andersson SO, Holmberg L, Bergstrom R. Prognostic factors in progression-free survival and corrected survival in patients with advanced prostatic cancer: results from a randomized study comprising 150 patients treated with orchiectomy or estrogens. J Urol. 1991 Nov;146(5):1327-32.
Johansson JE, Holmberg L, Johansson S, Bergstrom R, Adami HO. Fifteen-year survival in prostate cancer. A prospective, population-based study in Sweden. JAMA. 1997 Feb 12;277(6):467-71.
Jones HB, Betton GR, Bowdler AL, McFarquhar RL, Middleton BJ, Lunglmayr G. Pathological and morphometric assessment of testicular parameters in patients with metastatic prostate cancer following treatment with either the antiandrogen Casodex (ZM176,334) or bilateral orchidectomy. Urol Res. 1994;22(3):191-5. [pmid: 7992465].
Jordan WP Jr, Blackard CE, Byar DP. Reconsideration of orchiectomy in the treatment of advanced prostatic carcinoma. South Med J. 1977 Dec;70(12):1411-3.
Jorgensen T, Muller C, Kaalhus O, Danielsen HE, Tveter KJ. Extent of disease based on initial bone scan: important prognostic predictor for patients with metastatic prostatic cancer. Experience from the Scandinavian Prostatic Cancer Group Study No. 2 (SPCG-2). Eur Urol. 1995;28(1):40-6. [pmid: 8521893].
Jorgensen T, Tveter KJ, Jorgensen LH. Total androgen suppression: experience from the Scandinavian Prostatic Cancer Group Study No. 2. Eur Urol. 1993;24(4):466-70. [pmid: 8287887].
Jungwirth A, Mack D, Frick J. D2 prostate cancer-half dosage of the LHRH-agonists is sufficient for complete androgen deprivation. Eur J Cancer. 1995;31(1):128-9.
Jurincic CD, Horlbeck R, Klippel KF. Combined treatment (goserelin plus flutamide) versus monotherapy (goserelin alone) in advanced prostate cancer: A randomized study. Semin Oncol. 1991 Oct;18(5 Suppl 6):21-5.
Jurincic CD, Winkler C, Horlbeck R, Gasser A, Klippel KF. The treatment of advanced prostate carcinoma with goserelin acetate (Zoladex (r)) and goserelin acetate plus flutamide (Fugerel (r)). Dtsch Z Onkol. 1992;24(3):65-70.
Kaisary AV. Antiandrogen monotherapy in the management of advanced prostate cancer. Eur Urol. 1997;31(Suppl 2):14-9. [pmid: 9074906].
Kaisary AV. Current clinical studies with a new nonsteroidal antiandrogen, Casodex. Prostate Suppl. 1994;5:27-33. [pmid: 8172713].
Kaisary AV, Ryan PG, Turkes A, Peeling WB, Griffiths K. A comparison between surgical orchidectomy and LH-RH analogue ('Zoladex', ICI 118,630) in the treatment of advanced prostatic carcinoma-a multi-centre clinical study. Prog Clin Biol Res. 1988;260:89-100. [pmid: 2966408].
Kaisary AV, Tyrrell CJ, Beacock C, Lunglmayr G, Debruyne F. A randomised comparison of monotherapy with Casodex 50 mg daily and castration in the treatment of metastatic prostate carcinoma. Casodex Study Group. Eur Urol. 1995;28(3):215-22. [pmid: 8536775].
Kaisary AV, Tyrrell CJ, Peeling WB, Griffiths K. Comparison of LHRH analogue (Zoladex) with orchiectomy in patients with metastatic prostatic carcinoma. Br J Urol. 1991 May;67(5):502-8.
Kassem NY, Neri RO, Munroe JS. B-27. Effect of flutamide, an antiandrogen, on stage D cancer of the prostate. Clin Pharmacol Ther. 1981;29(2).
Kay R. Competing risks, interactions and crossing hazards. Recent Results Cancer Res. 1988;111:67-74. [pmid: 3175312].
Kay R. Treatment effects in competing-risks analysis of prostate cancer data. Biometrics. 1986;42(1):203-11. [pmid: 3521753].
Kelly WK, Scher HI. Prostate cancer: how can a common disease be so controversial?. Curr Opin Oncol. 1994;6(3):318-31. [pmid: 8080862].
Kelly WK, Slovin S, Scher HI. Steroid hormone withdrawal syndromes. Pathophysiology and clinical significance. Urol Clin North Am. 1997 May;24(2):421-31.
Kennealey GT, Vogelzang NJ, Soloway MS, Schellhammer P, Sharifi R, Block N, Venner P, Patterson L, Sarosdy M, Jones J, et al. Analysis of time to treatment failure by extent of disease and race in a randomized, multicenter trial comparing Casodex (bicalutamide) (C) with Eulexin (flutamide) (E), each combined with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Kent JR, Bischoff AJ, Arduino LJ, Mellinger GT, Byar DP, Hill M, Kozbur X. Estrogen dosage and suppression of testosterone levels in patients with prostatic carcinoma. J Urol. 1973 May;109(5):858-60.
Keuppens F, Denis L, Smith P, Carvalho AP, Newling D, Bond A, Sylvester R, De Pauw M, Vermeylen K, Ongena P. Zoladex and flutamide versus bilateral orchiectomy. A randomized phase III EORTC 30853 study. The EORTC GU Group. Cancer. 1990 Sep 1;66(5 Suppl):1045-57.
Keuppens F, Whelan P, Carneiro de Moura JL, Newling D, Bono A, Denis L, Robinson M, Mahler C, Sylvester R, De Pauw M, et al. Orchidectomy versus goserelin plus flutamide in patients with metastatic prostate cancer (EORTC 30853). European Organization for Research and Treatment of Cancer-Genitourinary Group. Cancer. 1993 Dec 15;72(12 Suppl):3863-9.
Kienle E, Lubben G. Efficacy and safety of leuprorelin acetate depot for prostate cancer. The German Leuprorelin Study Group. Urol Int. 1996;56 Suppl:1:23-30.
Kirby R, Fitzpatrick J, Kirby M, et al. A shared care for prostate diseases. ISIS Medical Media; 1994.
Kirk D. Phase III trials. Medical Research Council. Prog Clin Biol Res. 1988;260:77-87. [pmid: 3283772].
Kirk D. Trials and tribulations in prostatic cancer. Br J Urol. 1987 May;59(5):375-9. [pmid: 3297229].
Klein EA. Hormone therapy for prostate cancer: a topical perspective. Urology. 1996 Jan;47(1A Suppl):3-12. [pmid: 8560675].
Klijn JG, de Voogt HJ, Studer UE, Schroder FH, Sylvester R, De Pauw M. Short-term versus long-term addition of cyproterone acetate to buserelin therapy in comparison with orchidectomy in the treatment of metastatic prostate cancer. European Organization for Research and Treatment of Cancer-Genitourinary Group. Cancer. 1993 Dec 15;72(12 Suppl):3858-62.
Klioze SS, Miller MF, Spiro TP. A randomized, comparative study of buserelin with DES/orchiectomy in the treatment of stage D2 prostatic cancer patients. Am J Clin Oncol. 1988;11(Suppl 2):S176-S182. [pmid: 3149455].
Klosterhalfen H, Becker H. Results of a 10-year randomised prospective study in metastasised prostate cancer. Aktuel Urol. 1987;18(5):234-6.
Klotz LH, Sogani PC, Block NL. Summary of intermittent endocrine therapy for advanced prostate cancer (by Lawrence H. Klotz, MD, Harry W. Herr, MD, Michael J. Morse, MD, and Willet F. Whitmore, Jr., MD). 1986. Semin Urol Oncol. 1997 May;15(2):117-22.
Knonagel H, Bolle JF, Hering F, Senn E, Hodel T, Neuenschwander H, Biedermann C. [Therapy of metastatic prostatic cancer by orchiectomy plus Anandron versus orchiectomy plus placebo. Initial results of a randomized multicenter study]. Helv Chir Acta. 1989 Aug;56(3):343-5.
Kolvenbag GJ, Blackledge GR. Worldwide activity and safety of bicalutamide: A summary review. Urology. 1996 Jan;47(1A Suppl):70-9.
Kolvenbag GJ, Furr BJ. Bicalutamide ('Casodex') development: from theory to therapy. Cancer J Sci Am. 1997;3(4):192-203. [pmid: 9263623].
Kolvenbag GJ, Blackledge GR, Gotting-Smith K. Bicalutamide (Casodex) in the treatment of prostate cancer: History of clinical development. Prostate. 1998 Jan 1;34(1):61-72.
Konety BR, Getzenberg RH. Novel therapies for advanced prostate cancer. Semin Urol Oncol. 1997 Feb;15(1):33-42.
Koutsilieris M, Tolis G. Long-term follow-up of patients with advanced prostatic carcinoma treated with either buserelin (HOE 766) or orchiectomy: Classification of variables associated with disease outcome. Prostate. 1985;7(1):31-9. [pmid: 3936031].
Kozlowski JM, Ellis WJ, Grayhack JT. Advanced prostatic carcinoma. Early versus late endocrine therapy. Urol Clin North Am. 1991 Feb;18(1):15-24.
Krahn MD, Mahoney JE, Eckman MH, Trachtenberg J, Pauker SG, Detsky AS. Screening for prostate cancer. A decision analytic view. JAMA. 1994 Sep 14;272(10):773-80.
Kuban DA, El-Mahdi AM, Schellhammer PF. Potential benefit of improved local tumor control in patients with prostate carcinoma. Cancer. 1995b May 1;75(9):2373-82.
Kuban DA, El-Mahdi AM, Schellhammer PF. Prognosis in patients with local recurrence after definitive irradiation for prostatic carcinoma. Cancer. 1989 Jun 15;63(12):2421-5.
Kuban DA, El-Mahdi AM, Schellhammer PF. Prostate-specific antigen for pretreatment prediction and posttreatment evaluation of outcome after definitive irradiation for prostate cancer. Int J Rad Oncol Biol Phys. 1995a May 15;32(2):307-16.
Kuhn JM, Billebaud T, Navratil H, Moulonguet A, Fiet J, Grise P, Louis JF, Costa P, Husson JM, Dahan R, et al. Prevention of the transient adverse effects of a gonadotropin-releasing hormone analogue (buserelin) in metastatic prostatic carcinoma by administration of an antiandrogen (nilutamide). N Engl J Med. 1989 Aug 17;321(7):413-8.
Kurth, Denis L, Newling DW, Copper W, Blackledge GRP. Panel discussion 2. Prostate. 1994;24(Suppl 5).
Labrie F. Intracrinology: Its impact on prostate cancer. Curr Opin Urol. 1993;3(5):381-7.
Labrie F, Belanger A, Cusan L, Labrie C, Simard J, Luu-The V, Diamond P, et al. History of LHRH agonist and combination therapy in prostate cancer. Endocrine Rel Cancer. 1996;3:243-78.
Labrie F, Belanger A, Dupont A, Luu-The V, Simard J, Labrie C. Science behind total androgen blockade: From gene to combination therapy. Clin Invest Med. 1993;16(6):475-92. [pmid: 8013153].
Labrie F, Belanger A, Simard J, Labrie C, Dupont A. Combination therapy for prostate cancer. Endocrine and biologic basis of its choice as new standard first-line therapy. Cancer. 1993 Feb 1;71(3 Suppl):1059-67.
Labrie F, Dupont A, Belanger A, Cusan L, Lacourciere Y, Monfette G, Laberge JG, Emond JP, Fazekas AT, Raynaud JP, et al. New hormonal therapy in prostatic carcinoma: Combined treatment with an LHRH agonist and an antiandrogen. Clin Invest Med. 1982;5(4):267-75. [pmid: 6819101].
Labrie F, Dupont A, Belanger A, Giguere M, Lacoursiere Y, Emond J, Monfette G, Bergeron V. Combination therapy with flutamide and castration (LHRH agonist or orchiectomy) in advanced prostate cancer: A marked improvement in response and survival. J Steroid Biochem. 1985;23(5B):833-41. [pmid: 2934579].
Labrie F, Dupont A, Cusan L, Gomez J, Emond J, Monfette G. Combination therapy with flutamide and medical (LHRH agonist) or surgical castration in advanced prostate cancer: 7-year clinical experience. J Steroid Biochem Mol Biol. 1990;37(6):943-50. [pmid: 2285608].
Labrie F, Dupont A, Cusan L, Manhes G, Bergeron N, Lacourciere Y, Pineault S, Belanger A, Monfette G, Emond J. Combination therapy with flutamide and castration: Its benefits at various stages of prostate cancer. Prog Clin Biol Res. 1989;303:161-7. [pmid: 2674982].
Labrie F, Dupont A, Emond J, Monfette G. Combination therapy in prostate cancer. Br Med J (Clin Res Ed). 1986 Nov 1;293(6555).
Lambley DG, Ware JW. Oral stilboestrol diphosphate ("Honvan") in the treatment of prostatic carcinoma: A clinical trial. Br J Urol. 1967;39(2):147-52. [pmid: 5337817].
Landis SH, Murray T, Bolden S, Wingo PA. Cancer Statistics, 1998. CA Cancer J Clin 1998 Jan-Feb;48(1):6-29.
Lee WR, Hanks GE, Schultheiss TE. The role of radiation therapy in the management of of stage T3-T4 prostate cancer: rationale, technique, and results with standard radiation, conformal therapy, proton and neutron beam therapy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 790-8.
Lerner SE, Blute WR, Zincke H. Primary surgery for clinical stage T3 adenocarcinoma of the prostate. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 803-11.
Lillis P, Thompson IM. Should asymptomatic progression following definitive local treatment for prostate cancer be treated?. Hematol Oncol Clin North Am. 1996 Jun;10(3):703-12.
Litwin MS, Lubeck DP, Henning JM, Carroll PR. Differences in urologist and patient assessments of health related quality of life in men with prostate cancer: Results of the CaPSURE database. J Urol. 1998 Jun;159(6):1988-92.
Lo Re G, Veronesi A, Dal Bo V, Ciaccio B, Giannoni C, Miotto E, Talamini R, Francini M, Monfardini S. Treatment of advanced prostatic cancer with the LH-RH analogue, buserelin. A phase II study. Folia Oncol. 1989;12(1):42-7.
Lucas MD, Strijdom SC, Berk MM, Hart GA. Quality of life, sexual functioning and sex role identity after surgical orchiectomy in patients with prostatic cancer. Scand J Urol Nephrol. 1995 Dec;29(4):497-500.
Lund F, Rasmussen F. Flutamide versus stilboestrol in the management of advanced prostatic cancer. A controlled prospective study. Br J Urol. 1988 Feb;61(2):140-2.
Lunglmayr G. 'Zoladex' versus 'Zoladex' plus flutamide in the treatment of advanced prostate cancer. First interim analysis of an international trial. International Prostate Cancer Study Group. Prog Clin Biol Res. 1989;303:145-51. [pmid: 2528737].
Lunglmayr G. A multicenter trial comparing the luteinizing hormone releasing hormone analog Zoladex, with Zoladex plus flutamide in the treatment of advanced prostate cancer. The International Prostate Cancer Study Group. Eur Urol. 1990;18(Suppl 3):28-9. [pmid: 2151273].
Lunglmayr G. Efficacy and tolerability of Casodex in patients with advanced prostate cancer. Anticancer Drugs. 1995;6(4):508-13. [pmid: 7579554].
Lunn M, McNeil D. Applying Cox regression to competing risks. Biometrics. 1995;51(2):524-32. [pmid: 7662841].
Maatman TJ, Gupta MK, Montie JE. Effectiveness of castration versus intravenous estrogen therapy in producing rapid endocrine control of metastatic cancer of the prostate. J Urol. 1985 Apr;133(4):620-1.
MacFarlane JR, Tolley DA. Flutamide therapy for advanced prostatic cancer: A phase II study. Br J Urol. 1985;57(2):172-4. [pmid: 3986452].
Madsen PO, Pedersen JF, Knuth OE. [Hormone treatment in the prostatic cancer]. Urologe. 1969 Nov;8(6):330-3.
Madsen PO, Pedersen JF, Knuth OE. Endocrine treatment of cancer of the prostate. Wis Med J. 1970;69(7):177-81. [pmid: 4916084].
Mahler C, Denis LJ. Hormone refractory disease. Semin Surg Oncol. 1995 Jan;11(1):77-83.
Mahler CH, Akaza H, Boccardo F, et al. Secondary hormonal treatment. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 305-24.
Marshall V, Thompson P, Raghavan D, Zalcberg J. First report of Australian multicenter randomized prostate cancer trial: flutamide does not add to the effect of orchiectomy for metastatic prostate cancer [abstract]. Proc Annu Meet Am Assoc Cancer Res. 1992;33.
Martin WR, Chow MSS. Focus on nilutamide: a nonsteroidal antiandrogen for treatment of advanced prostate cancer. Formulary. 1996;31(2):105-12.
Maruoka M, Ando K, Nozumi K, et al. Endocrine therapy for prostatic cancer. Nippon Hinyokika Gakkai Zasshi. 1982;73(4):432-7. [pmid: 7120711].
Matzkin H, Perito PE, Soloway MS. Prognostic factors in metastatic prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3788-92.
Mayer FJ, Crawford ED. The role of endocrine therapy in the management of local and distant recurrence of prostate cancer following radical prostatectomy or radiation therapy. Urol Clin North Am. 1994 Nov;21(4):707-15.
Mazeman E, Bertrand P. Early versus delayed hormonal therapy in advanced prostate cancer. Eur Urol. 1996;30(Suppl 1):40-3.
McEvoy GK, editor. Diethylstilbestrol, diethylstilbestrol diphosphate. In: AHFS Drug Information 1997. Bethesda: American Society of Health-system Pharmacists; 1997. p. 2399-401.
McGowan D. Metastatic prostate cancer: Quality of life and cost considerations. Oncology (USA). 1994;8(11 Suppl):30-2. [pmcid: 419372].
McLeod DG. Antiandrogenic drugs. Cancer. 1993 Feb 1;71(3 Suppl):1046-9. [pmid: 8428326].
McLeod DG. Hormonal therapy in the treatment of carcinoma of the prostate. Cancer. 1995;75(7 Suppl):1914-9.
McLeod DG. Tolerability of nonsteroidal antiandrogens in the treatment of advanced prostate cancer. Oncologist. 1997;2(1):18-27. [pmid: 10388026].
McLeod DG, Benson RC Jr, Eisenberger MA, Crawford ED, Blumenstein BA, Spicer D, Spaulding JT. The use of flutamide in hormone-refractory metastatic prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3870-3.
McLeod DG, Crawford ED, Blumenstein BA, Eisenberger MA, Dorr FA. Controversies in the treatment of metastatic prostate cancer. Cancer. 1992 Jul 1;70(1 Suppl):324-8.
McLeod DG, Crawford ED, DeAntoni EP. Combined androgen blockade: The gold standard for metastatic prostate cancer. Eur Urol. 1997;32(Suppl 3):70-7. [pmid: 9267789].
McLeod DG, Kolvenbag GJ. Defining the role of antiandrogens in the treatment of prostate cancer. Urology. 1996 Jan;47(1A Suppl):85-9.
Medical Research Council Working Party Investigators Group. Immediate versus deferred treatment for advanced prostatic cancer: Initial results of the Medical Research Council Trial. Br J Urol. 1997 Feb;79(2):235-46.
Metz R, Namer M, Adenis L, Audhuy B, Bugat R, Colombel P, Couette JE, Grise P, Khater R, LePorz B, et al. Zoladex as primary therapy in advanced prostatic cancer. A French cooperative trial. Am J Clin Oncol. 1988;11(Suppl 2):S112-S114. [pmid: 2977263].
Middleton RG, Thompson IM, Austenfeld MS, Cooner WH, Correa RJ, Gibbons RP, Miller HC, Oesterling JE, Resnick MI, Smalley SR, et al. Prostate Cancer Clinical Guidelines Panel Summary report on the management of clinically localized prostate cancer. The American Urological Association. J Urol. 1995 Dec;154(6):2144-8.
Migliari R, Scarpa RM, Campus G, De Lisa A, Zucca I, D'Atri M, Serra A, Usai E. Evaluation of efficacy and tolerability of nilutamide and buserelin inthe treatment of advanced prostate cancer. Arch Ital Urol Nefrol Androl. 1991 Mar;63(1):147-53.
Miller DK, Homan SM. Determining transition probabilities: Confusion and suggestions. Med Decis Making. 1994 Jan;14(1):52-8.
Moffat LE. Comparison of Zoladex, diethylstilbestrol and cyproterone acetate treatment in advanced prostate cancer. Eur Urol. 1990;18(Suppl 3):26-7. [pmid: 2151272].
Moher D, Jadad A, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: An annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
Moinpour CM, Savage M, Lovato L, Troxel A, Skeel R, Eisenberger MA, Crawford ED, Meyskens FL Jr. Quality of life (QOL) endpoints in advanced stage prostate cancer: A randomized, double blind study comparing flutamide to placebo in orchiectomized stage D2 prostate patients (PTS) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1997;16.
Moinpour CM, Savage MJ, Troxel A, Lovato LC, Eisenberger M, Veith RW, Higgins B, Skeel R, Yee M, Blumenstein BA, et al. Quality of life in advanced prostate cancer: Results of a randomized therapeutic trial. J Natl Cancer Inst. 1998;90(20):1537-44. [pmid: 9790546].
Montie JE, Pienta KJ. Review of the role of androgenic hormones in the epidemiology of benign prostatic hyperplasia and prostate cancer. Urology. 1994;43(6):892-9. [pmid: 7515207].
Mora MJ, Extramiana J, Paniagua P, Gonzalez P, Manas A, Perez MJ, Navarro J, Arrizabalaga M. [Orchiectomy and buserelin in combination with flutamide: comparative results in metastatic prostatic carcinoma]. Actas Urol Esp. 1991;15(6):548-52. [pmid: 1792994].
Mordkin RM, Hayes WS, Kuettel MR, Lynch JH. Management of locally advanced prostate cancer. Oncology (Huntingt). 1996;10(9):1289-300. [pmcid: 419372]. [pmid: 8882922].
Morote J, Vallejo C, Lorente JA, Encabo G, Lopez Pacios MA, de Torres JA, Soler Rosello A. [Final results of complete hormone blockade versus monotherapy in prostatic metastatic cancer. PSA implications]. Actas Urol Esp. 1995;19(8):604-10. [pmid: 8669327].
Morote Robles J, Vila Barja J, Lopez Pacios MA, de Torres Mateos JA, Soler Rosello A. [Complete hormonal blockade vs. monotherapy in the management of metastasizing prostatic cancer]. Actas Urol Esp. 1992;16(6):451-4. [pmid: 1509913].
Mosteller F, Gilbert JP, McPeek B. Reporting standards and research strategies for controlled trials. Agenda for the editor. Controlled Clin Trials. 1980;1:37-58.
Moul JW. Contemporary hormonal management of advanced prostate cancer. Oncology (Huntingt). 1998 Apr;12(4):499-505. [pmcid: 419372]. [pmid: 9575524].
Mulloy WP. Comparative efficacy of hormonal therapy used alone or in combination for treatment of prostatic carcinoma [abstract]. In: Fourth International Congress on Anti-cancer Chemotherapy; 1993 Feb 2-5; Paris, France. p. 102.
Mulrow CD, Oxman AD, editors. Cochrane Collaboration Handbook [updated 9 December 1996]. Available in The Cochrane Library [database on disk and CDROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Murphy GP. Follow-up evaluation of national prostatic cancer project protocols andother studies. Urology. 1994;44(6 Suppl):61-6.
Nabors W, Crawford ED. Luteinizing hormone releasing hormone agonists: The US experience. J Int Med Res. 1990;18(Suppl 1):31-4. [pmid: 2108884].
Naito S. New development of endocrine therapy in prostate cancer. Jpn J Cancer Chemother. 1996;23(6):684-8.
Namer M, Amiel J, Toubol J. Anandron (RU 23908) associated with orchiectomy in stage D prostate cancer. Preliminary results of a randomized, double-blind study. Am J Clin Oncol. 1988;11(Suppl 2):S191-S196. [pmid: 3071952].
Namer M, Toubol J, Caty A, Couette JE, Douchez J, Kerbrat P, Droz JP. A randomized double-blind study evaluating Anandron associated with orchiectomy in stage D prostate cancer. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):909-15.
Navratil H. Double-blind study of Anandron versus placebo in stage D2 prostate cancer patients receiving buserelin. Results on 49 cases from a multicentre study. Prog Clin Biol Res. 1987;243A:401-10. [pmid: 3116551].
Neumann F. Use of cyproterone acetate in animal and clinical trials. Gynecol Invest. 1971;2(1):150-79. [pmid: 4949823].
Newling DW. Clinical developments in prostate cancer: introduction. Prostate. 1994;24(Suppl 5).
Newling DW. [Clinical protocols in treatment of prostatic carcinoma in Europe. The role of EORTC and other organizations]. Urologe A. 1995;34(5):374-81. [pmid: 7483153].
Newling DW. European trials and the management of prostate cancer. Semin Surg Oncol. 1995;11(1):65-71. [pmid: 7754278].
Newling DW. The palliative therapy of advanced prostate cancer, with particular reference to the results of recent European clinical trials. Br J Urol. 1997 Mar;79(Suppl 1):72-81. [pmid: 9088277].
Newling DW. The use of flutamide as monotherapy in the treatment of advanced prostate cancer. Prog Clin Biol Res. 1989;303:117-21. [pmid: 2674980].
Newling DW, Denis L. Closing remarks. Prostate. 1994;24(Suppl 5).
Newling DW, Denis L, Vermeylen K. Orchiectomy versus goserelin and flutamide in the treatment of newly diagnosed metastatic prostate cancer. Analysis of the criteria of evaluation used in the European Organization for Research and Treatment of Cancer-Genitourinary Group Study 30853. Cancer. 1993 Dec 15;72(12 Suppl):3793-8.
Newling DW, Pavone Macaluse M, Smith P, de Voogt HJ, Robinson MR, Schroder FH, Denis L, Jones WG, de Pauw M, Sylvester R. Update of EORTC clinical trials in prostate cancer. The EORTC Genito-Urinary Group. Semin Urol. 1992 Feb;10(1):65-71.
Nicholson S, Waxman J. Prostate cancer and endocr therapy. Endocr Rel Cancer. 1997;4(2):141-52.
Nord E. Methods for quality adjustment of life years. Soc Sci Med. 1992;34:560-6.
Oesterling J, Fuks Z, Lee CT, et al. Cancer of the prostate. In: DeVita VT Jr, Hellman S, Rosenberg SA, editors. Cancer: Principles and practice of oncology. 5th ed. Philadelphia: Lippincott-Raven; 1997. p. 1322-86.
Oosterlinck W, Casselman J, Mattelaer J, Van Velthoven R, Kurjatkin O, Schulman C. Tolerability and safety of flutamide in monotherapy, with orchiectomy or with LHRH-a in advanced prostate cancer patients. A Belgian multicenter study of 905 patients. Eur Urol. 1996;30(4):458-63. [pmid: 8977067].
Ostri P, Bonnesen T, Nilsson T, Frimodt-Moller C. Treatment of symptomatic metastatic prostatic cancer with cyproterone acetate versus orchiectomy: A prospective randomized trial. Urol Int. 1991;46(2):167-71. [pmid: 1711250].
Panvichian R, Pienta KJ. Hormonal and chemotherapeutic systemic therapy for metastatic prostate cancer. Cancer Control. 1996;3(6):493-500. [pmid: 10764507].
Parametric cost estimating reference manual: inflation calculator. NASA [cited Jan 16, 1998]. Available from: URL: http://www.jsc.nasa.gov/bu2/inflate.html.
Parmar H, Edwards L, Phillips RH, Allen L, Lightman SL. Orchiectomy versus long-acting D-Trp-6-LHRH in advanced prostatic cancer. Br J Urol. 1987;59(3):248-54. [pmid: 2952213].
Parmar H, Edwards LE, Phillips RH, Charlton C, Lightman SI. Medical or surgical orchidectomy. BMJ. 1991 May 25;302(6787). [pmcid: 318487].
Parmar H, Phillips RH, Edwards L, Lightman SL. Medical versus surgical orchiectomy in advanced prostatic cancer. GnRH Analogues Cancer Hum Reprod. 1990;3:103-16.
Parmar H, Phillips RH, Lightman SL, Edwards L. How would you like to have an orchidectomy for advanced prostatic cancer?. Am J Clin Oncol. 1988;11(Suppl 2):S160-S168. [pmid: 2977271].
Parmar H, Phillips RH, Lightman SL, Edwards L, Allen L, Schally AV. Randomised controlled study of orchidectomy vs long-acting D-Trp-6-LHRH microcapsules in advanced prostatic carcinoma. Lancet. 1985 Nov 30;2(8466):1201-5.
Partin AW, Kattan MW, Subong EN, Walsh PC, Wojno KJ, Oesterling JE, Scardino PT, Pearson JD. Combination of prostate-specific antigen, clinical stage, and Gleason score to predict pathological stage of localized prostate cancer: A multi-institutional update. JAMA. 1977 May;277(18):1445-51.
Pastorello M, Mora A, Magnanini A. Treatment of prostatic cancer. A randomized study. Urologia. 1982;49(2):281-5.
Patrick DL, Erickson P. Health status and health policy. Allocating resources to health care. New York: Oxford University Press; 1993.
Pavone-Macaluso M. Medroxyprogesterone acetate in the treatment of prostatic cancer: Preliminary results of EORTC trial 30761 comparing MPA with stilbestrol and with cyproterone acetate. In: Campio L, editor. Role of medroxyprogesterone in endocrine-related tumors. Vol. 2. New York: Raven Press; 1983. p. 183-90.
Pavone-Macaluso M, de Voogt HJ, Viggiano G, Barasolo E, Lardennois B, de Pauw M, Sylvester R. Comparison of diethylstilbestrol, cyproterone acetate and medroxyprogesterone acetate in the treatment of advanced prostatic cancer: Final analysis of a randomized phase III trial of the European Organization for Research on Treatment of Cancer Urological Group. J Urol. 1986 Sep;136(3):624-31.
Pavone-Macaluso M, Ingargiola GB, de Voogt H, Viggiano G, Barasolo E, Lardennois B, De Pauw M, Sylvester R. Cyproterone acetate versus medroxyprogesterone acetate versus diethylstilbestrol in the treatment of prostate cancer: Results from EORTC Study 30761. Prog Clin Biol Res. 1987;243A:379-82. [pmid: 2958862].
Pavone-Macaluso M, Lund F, Mulder JH, Smith PH, De Pauw M, Sylvester R. EORTC protocols in prostatic cancer. An interim report. Scand J Urol Nephrol Suppl. 1980;55:163-8. [pmid: 6938020].
Pavone-Macaluso M, Martinez-Pineiro JA, de Voogt H, Lardennois B, Nasta A, Zolfanelli R, Barasolo E, De Pauw M, Suciu S, Sulvester R. [Treatment of prostatic cancer: medroxyprogesterone acetate, diethylstilbestrol and cyproterone acetate. Provisional report of a random study by the genito-urinary cooperative group of the EORTC]. Arch Esp Urol. 1982 Sep-Oct;35(5):304-11.
Pavone-Macaluso M, Pavone C, Serretta V, Daricello G. Antiandrogens alone or in combination for treatment of prostate cancer: The European experience. Urology. 1989 Oct;34(4 Suppl):27-36. [pmcid: 434513].
Pavone-Macaluso M, Schroder FH, de Voogt HJ, Viggiano G, Barasolo E, Lardennois B, de Pauw M, Sylvester R, Smith PH, Suciu S. EORTC protocol 30761: A randomized study of non-metastatic and metastatic prostatic cancer treated by cyproterone acetate versus diethylstilbestrol and medroxyprogesterone acetate. European Organization for Research on Treatment of Cancer Urological Group. Prog Clin Biol Res. 1989;303:111-6. [pmid: 2528735].
Pavone-Macaluso M, Serretta V, Daricello G, Pavone C, Cacciatore M, Romano C, Cavallo N. Is there a role for pure antiandrogens in the treatment of advanced prostatic cancer?. Prog Clin Biol Res. 1990;350:149-57. [pmid: 2201041].
Peeling WB. A comparison between surgical orchidectomy and the LHRH agonist 'Zoladex' (ICI 188630) in the treatment of metastatic cancer of the prostate. Prog Clin Biol Res. 1989a;303:41-5. [pmid: 2528738].
Peeling WB. Phase III studies to compare goserelin (Zoladex) with orchiectomy and with diethylstilbestrol in treatment of prostatic carcinoma. Urology. 1989b May;33(5 Suppl):45-52. [pmid: 2523611].
Peeling WB. Randomised controlled trial of treatment of patients with prostatic cancer: Orchidectomy, diethylstilboestrol, cyproterone acetate. Monogr Ser Eur Organ Res Treat Cancer. 1984;13:171-2.
Peetermans C, Roux E. Androcur 50 in the treatment of prostatic carcinoma. Belgian multicentric study with the participation of 30 urologists. Acta Urol Belg. 1994 Apr;62(1):77-82.
Pepperell RJ. Will gonadotrophin releasing hormone analogues profoundly affect gynaecological practice?. Aust N Z J Obstet Gynaecol. 1985 Nov;25(4):285-8. [pmid: 3938950].
Perez CA. Prostate. In: Perez CA, Brady LW, editors. Principles and practice of radiation oncology. 3rd ed. Philadelphia: Lippincott-Raven; 1997. p. 1583-1694.
Periti P, Rizzo M, Mazzei T, Mini E. Depot leuprorelin acetate alone or with nilutamide in the treatment of metastatic prostate carcinoma: interim report of a multicenter, double-blind, placebo-controlled study [abstract]. Can J Infect. 1995;6(Suppl C).
Perren TJ, Clayton RN, Blackledge G, Bailey LC, Holder G, Lynch SS, Arkell DG, Cottam J, Farrar D, Young CH. Pharmacokinetic and endocrinological parameters of a slow-release depot preparation of the GnRH analogue ICI 118630 (zoladex) compared with a subcutaneous bolus and continuous subcutaneous infusion of the same drug in patients with prostatic cancer. Cancer Chemother Pharmacol. 1986;18(1):39-43. [pmid: 2944668].
Physician Data Query (PDQ) Database. Treatment of prostate cancer. Physician Data Query (PDQ) Information for Health Professionals. National Cancer Institute (NCI) web site. Available at: http://cancernet.nci.nih.gov/clinpdq/soa/Prostate_cancer_Physician.html. Last updated: 1/98; accessed February 4, 1998.
Pilepich MV. Combined radiation therapy and endocrine therapy in locally advanced prostate cancer. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 798-802.
Pilepich MV, Caplan R, Byhardt RW, Lawton CA, Gallagher MJ, Mesic JB, Hanks GE, Coughlin CT, Porter A, Shipley WU, et al. Phase III trial of androgen suppression using goserelin in unfavorable-prognosis carcinoma of the prostate treated with definitive radiotherapy: Report of the Radiation Therapy Oncology Group Protocol 85-31. J Clin Oncol. 1997 Mar;15(3):1013-21.
Pilepich MV, Caplan R, Byhardt RW, Lawton CA, Gallagher MJ, Mesic JB, Hanks GE, Coughlin CT, Porter A. Phase III trial of androgen suppression using goserelin in unfavorable prognosis carcinoma of the prostate treated with definitive radiotherapy (report of RTOG protocol 85-31) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Pilepich MV, Krall JM, al-Sarraf M, John MJ, Doggett RL, Sause WT, Lawton CA, Abrams RA, Rotman M, Rubin P, et al. Androgen deprivation with radiation therapy compared with radiation therapy alone for locally advanced prostatic carcinoma: A randomized comparative trial of the Radiation Therapy Oncology Group. Urology. 1995 Apr;45(4):616-23.
Pilepich MV, Winter K, Roach M, Russell AH, Sause W, Rubin P, Byhardt R, et al. Phase III Radiation Therapy Oncology Group (RTOG) trial 86-10 of androgen deprivation before and during radiotherapy in locally advanced carcinoma of the prostate [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1998;17.
Plosker GL, Brogden RN. Leuprorelin. A review of its pharmacology and therapeutic use in prostatic cancer, endometriosis and other sex hormone-related disorders. Drugs. 1994 Dec;48(6):930-67.
Polednak AP. Estimating the prevalence of cancer in the United States. Cancer. 1997 Jul 1;80(1):136-41. [pmid: 9210719].
Presant CA, Soloway MS, Klioze SS, Yakabow A, Presant SN, Mendez RG, Kennedy PS, Wyres MR, Naessig VL, Todd B, et al. Buserelin treatment of advanced prostatic carcinoma. Long-term follow-up of antitumor responses and improved quality of life. Cancer. 1987 May 15;59(10):1713-6.
Presti JC Jr. Complete androgen blockade for metastatic prostate cancer. West J Med. 1994 Feb;160(2):169-170. [pmid: 8160471].
Prestidge BR, Prete JJ, Buchholz TA, Friedland JL, Stock RG, Grimm PD, Bice WS. A survey of current clinical practice of permanent prostate brachytherapy in the United States. Int J Radiat Oncol Biol Phys. 1998 Jan 15;40(2):461-5.
Prostate Cancer Trialists' Collaborative Group. Maximum androgen blockade in advanced prostate cancer: An overview of 22 randomised trials with 3283 deaths in 5710 patients. Lancet. 1995 Jul 29;346(8970):265-9.
Radiation Therapy Oncology Group. Phase III trial of androgen suppression before and during radiation therapy for locally advanced prostatic cancer: Abstract report of RTOG 8610. Prostate Suppl. 1994;5:2-3. [pmid: 8172711].
Rana A, Chisholm GD, Khan M, Rashwan HM, Elton RA. Conservative management with symptomatic treatment and delayed hormonal manipulation is justified in men with locally advanced carcinoma of the prostate. Br J Urol. 1994;74(5):637-41. [pmid: 7827816].
Rana A, Habib FK, Halliday P, Ross M, Wild R, Elton RA, Chisholm GD. A case for synchronous reduction of testicular androgen, adrenal androgen and prolactin for the treatment of advanced carcinoma of the prostate. Eur J Cancer. 1995;31A(6):871-5. [pmid: 7646913].
Randal J. Survey shows M.D.s' ambivalence about maximum androgen blockade [news]. J Natl Cancer Inst. 1995;87(24):1827-9. [pmid: 7494222].
Reiter RE, Scardino PT, Miles BJ. Salvage radical prostatectomy for local recurrence of prostate cancer after radiation therapy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 817-28.
Ritter MA, Messing EM, Shanahan TG, Potts S, Chappell RJ, Kinsella TJ. Prostate-specific antigen as a predictor of radiotherapy response and patterns of failure in localized prostate cancer. J Clin Oncol. 1992 Aug;10(8):1208-17.
Robertson CN, Roberson KM, Padilla GM, O'Brien ET, Cook JM, Kim CS, Fine RL. Induction of apoptosis by diethylstilbestrol in hormone-insensitive prostate cancer cells. J Natl Cancer Inst. 1996 Jul 3;88(13):908-17.
Robinson MR. A further analysis of European Organization for Research and Treatment of Cancer protocol 30805.Orchidectomy versus orchidectomy plus cyproterone acetate versus low-dose diethylstilbestrol. Cancer. 1993 Dec 15;72(12 Suppl):3855-7.
Robinson MR. Complete androgen blockade: The EORTC experience comparing orchidectomy versus orchidectomy plus cyproterone acetate versus low-dose stilboestrol in the treatment of metastatic carcinoma of the prostate. Prog Clin Biol Res. 1987;243A:383-90. [pmid: 2958863].
Robinson MR. EORTC protocol 30805: A phase III trial comparing orchidectomy versus orchidectomy and cyproterone acetate and low dose stilboestrol in the management of metastatic carcinoma of the prostate. Prog Clin Biol Res. 1988;260:101-10. [pmid: 2966402].
Robinson MR. Is there a best endocrine management of prostatic carcinoma?. Prog Clin Biol Res. 1988;269:147-58. [pmid: 2969114].
Robinson MR, Smith PH, Macaluso MP, Sylvester R, de Voogt H. The EORTC Phase III trials in prostatic cancer. Prog Clin Biol Res. 1985;185A:243-9. [pmid: 3898132].
Robinson MR, Smith PH, Richards B, Newling DW, de Pauw M, Sylvester R. The final analysis of the EORTC Genito-Urinary Tract Cancer Co-Operative Group phase III clinical trial (protocol 30805) comparing orchidectomy, orchidectomy plus cyproterone acetate and low dose stilboestrol in the management of metastatic carcinoma of the prostate. Eur Urol. 1995;28(4):273-83. [pmid: 8575493].
Robson M, Dawson N. How is androgen-dependent metastatic prostate cancer best treated?. Hematol Oncol Clin North Am. 1996 Jun;10(3):727-47.
Rohl HF, Beuke HP. Effect of orchidectomy on serum concentrations of testosterone and dihydrotestosterone in patients with prostatic cancer. Scand J Urol Nephrol. 1992;26(1):11-4. [pmid: 1631501].
Roila F. Buserelin in the treatment of prostatic cancer. Biomed Pharmacother. 1989;43(4):279-85. [pmid: 2506941].
Rubben H, Altwein JE. [Advanced prostate cancer-a therapeutic dilemma?]. Urologe A. 1987 Jan;26(1):7-14.
Rubben H, Dijkman G, Ferrari P, et al. Treatment of hormone resistant disease. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd.; 1997. p. 325-42.
Rubin P. Editor's note. Int J Radiation Oncol Biol Physics. 1996;34(5):981-2.
Ruff P, Derman DP, Weaving A, Bezwoda WR. Sequential hormonal therapy and sequential hormonal and chemotherapy for advanced prostatic cancer. Oncology. 1989;46(5):288-92. [pmid: 2528705].
Rutqvist LE, Wilking N. Analogues of LHRH versus orchidectomy: Comparison of economic costs for castration in advanced prostate cancer. Br J Cancer. 1992;65(6):927-9. [pmid: 1616866].
Ryan PG, Peeling WB. U.K. trials of treatment for M1 prostatic cancer. The LH-RH analogue Zoladex vs. orchidectomy. Am J Clin Oncol. 1988;11(Suppl 2):S169-S172. [pmid: 2977272].
Sander S, Nissen-Meyer R, Aakvag A. Orchiectomy combined with cyproterone acetate or prednisone in the treatment of advanced prostatic carcinoma. A randomized clinical and endocrine study. Scand J Urol Nephrol. 1982;16(3):193-7. [pmid: 6219455].
Sandow J, Stoeckemann K, Jerabek-Sandow G. Pharmacokinetics and endocrine effects of slow release formulations of LHRH analogues. J Steroid Biochem Mol Biol. 1990;37(6):925-31. [pmid: 2126737].
Sanford EJ, Bowditch RR, Rohner TJ Jr, Bardin CW. Treatment of advanced prostatic cancer with flutamide. Pa Med. 1979;82(9):29-31.
Santen RJ, Thibault A, Myers C, Chung L. Meeting summary: Workshop conference on endocrine therapy of advanced prostate cancer, Airlie House, November 3-4, 1996. Urol Oncol. 1997;3(1):31-8. [pmid: 21227050].
Sarosdy MF, Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Vogelzang NJ, Chodak GW, Klein EA, et al. Comparison of four combined androgen blockade (CAB regimens for stage D2 prostate cancer) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1998a;17.
Sarosdy MF, Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Vogelzang NJ, Chodak GW, Klein EA, et al. Comparison of goserelin and leuprolide in combined androgen blockade therapy. Urology. 1998b Jul;52(1):82-8. [pmcid: 111060].
Sasagawa T, Tomita Y, Terunuma M, Tanikawa T, Kawakami Y, Nishiyama T, Watanabe T, Sato S. A clinical study of prostatic cancer. Nishinihon J Urol. 1991;53(1):17-20.
Schellhammer P. Bicalutamide (Casodex). Exp Opin Invest Drugs. 1996;5(12):1707-22.
Schellhammer PF. Combined androgen blockade for the treatment of metastatic cancer of the prostate. Urology. 1996 May;47(5):622-8. [pmid: 8650856].
Schellhammer P, Sharifi R, Block N, Soloway M, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. Maximal androgen blockade for patients with metastatic prostate cancer: Outcome of a controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy. Casodex Combination Study Group. Urology. 1996b Jan;47(1A Suppl):54-60.
Schellhammer P, Sharifi R, Block N, Soloway M, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer. Casodex Combination Study Group. Urology. 1995 May;45(5):745-52.
Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Vogelzang NJ, Schellenger JJ, Kolvenbag GJ. Clinical benefits of bicalutamide compared with flutamide in combined androgen blockade for patients with advanced prostatic carcinoma: Final report of a double-blind, randomized, multicenter trial. Casodex Combination Study Group. Urology. 1997 Sep;50(3):330-6. [pmcid: 115867].
Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Vogelzang NJ, Chen Y, Kolvenbag GJ. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate carcinoma. Analysis of time to progression. CASODEX Combination Study Group. Cancer. 1996a Nov 15;78(10):2164-9.
Schellhammer PF, Vogelzang NJ, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Jones JA, Kennealey GT, et al. Updated results of a randomized, double-blind trial in 813 previously untreated metastatic prostate cancer (CAP) patients (PTS) comparing the antiandrogens Casodex (bicalutamide) and Eulexin (flutamide) in combination with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Scher HI. Prostatic cancer: Are we closer to rational treatment selection?. Curr Opin Oncol. 1992;4(3):442-54. [pmid: 1379831].
Scher HI, Fossa S. Prostate cancer in the era of prostate-specific antigen. Curr Opin Oncol. 1995;7(3):281-91. [pmid: 7544627].
Schering Corporation. Eulexin® (flutamide) capsules prescribing information. Kenilworth, NJ: 1996 Jun.
Schroder FH. Cyproterone acetate-mechanism of action and clinical effectiveness in prostate cancer treatment. Cancer. 1993 Dec 15;72(12 Suppl):3810-5. [pmid: 8252496].
Schroder FH. Early versus delayed endocrine treatment in metastatic prostatic cancer. Prog Clin Biol Res. 1989;303:253-60. [pmid: 2674988].
Schroder FH. Is there a best endocrine treatment of prostate cancer?. J Clin Endocrinol Metab. 1995 Apr;80(4):1071-4. [pmid: 7714069].
Schroeder FH. Treatment of prostatic cancer: The EORTC experience-preliminary results of prostatic carcinoma trials. Prostate. 1984;5(2):193-8. [pmid: 6231535].
Schulman CC. Neoadjuvant androgen blockade prior to prostatectomy: A retrospective study and critical review. Prostate Suppl. 1994;5:9-14. [pmid: 7513532].
Schulze H, Kaldenhoff H, Senge T. Evaluation of total versus partial androgen blockade in the treatment of advanced prostatic cancer. Urol Int. 1988;43(4):193-7. [pmid: 2973169].
Seely JH. Phase III studies in prostatic cancer with leuprolide acetate. J Androl. 1987 Jan-Feb;8(1):S23-S26. [pmid: 3104263].
Shaheen JA, Amin M, Harty JI. Patient compliance in treatment of prostate cancer with luteinizing hormone-releasing hormone (LHRH) agonist. Urology. 1993;42(5):533-5. [pmcid: 434513]. [pmid: 8236595].
Sharifi R, Chodak G, Venner P, Block N, Callahan-Squire M, Jones J. Casodex vs castration in treatment of stage D2 prostate cancer: prostate-specific antigen (PSA) as a measure of outcome [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1993;12.
Sharifi R, Lee M, Ojeda L, Ray P, Stobnicki M, Guinan P. Comparison of leuprolide and diethylstilbestrol for stage D2 adenocarcinoma of prostate. Urology. 1985;26(2):117-24. [pmid: 3927551].
Shearer RJ, Hendry WF, Ferguson JD. Oestrogen treatment in carcinoma of the prostate. BMJ. 1973 Jul 7;3(870). [pmcid: 117452].
Slack NH, Brady MF, Murphy GP. Stable versus partial response in advanced prostate cancer. Prostate. 1984;5(4):401-15. [pmid: 6377284].
Small EJ. Prostate cancer. Curr Opin Oncol. 1997;9(3):277-86. [pmid: 9229151].
Small EJ, Schellhammer P, Venner P, Haas G, Nieh P, Seabaugh DR, Patterson AL, Klein E, Wajsman Z, Furr B, et al. A double-blind assessment of antiandrogen withdrawal from casodex (C) or eulexin (E) therapy while continuing luteinizing hormone releasing hormone analog (LHRH-a) therapy for patients (PTS) with stage D2 prostate cancer (PCA) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Small EJ, Vogelzang NJ. Second-line hormonal therapy for advanced prostate cancer: A shifting paradigm. J Clin Oncol. 1997 Jan;15(1):382-8.
Smith DC. Secondary hormonal therapy. Semin Urol Oncol. 1997;15(1):3-12. [pmid: 9050134].
Smith DC, Pienta KJ. The use of prostate-specific antigen as a surrogate end point in the treatment of patients with hormone refractory prostate cancer. Urol Clin North Am. 1997 May;24(2):433-7.
Smith JA Jr. Luteinizing hormone-releasing hormone (LH-RH) analogs in treatment of prostatic cancer. Clinical perspective. Urology. 1986;27(1 Suppl):9-15. [pmid: 3079936].
Smith JA Jr, Janknegt RA, Abbou CC, de Gery A. Effect of androgen deprivation therapy on local symptoms and tumour progression in men with metastatic carcinoma of the prostate. Eur Urol. 1997;31(Suppl 3):25-9. [pmid: 9101212].
Smith JA Jr, Lange PH, Janknegt RA, Abbou CC, deGery A. Serum markers as a predictor of response duration and patient survival after hormonal therapy for metastatic carcinoma of the prostate. J Urol. 1997;157(4):1329-34. [pmid: 9120932].
Smith PH. Deferred therapy in patients with advanced disease. Cancer. 1993;71(3 Suppl):1074-7. [pmid: 8428330].
Smith PH. Hormonal manipulation of metastatic prostate cancer. Curr Opin Urol. 1995;5(5):243-5.
Smith PH. Hormone therapy: An overview. Cancer Surv. 1995;23:171-81. [pmid: 7621456].
Smith PH. Oestrogens reconsidered. Semin Surg Oncol. 1995 Jan;11(1):72-6. [pmid: 7754279].
Smith PH. Prostate cancer. Endocrine and cytotoxic therapy. Recent Results Cancer Res. 1981;78:154-72. [pmid: 7022593].
Smith PH, Akdas A, Mason MK, Richards B, Robinson MR, De Pauw M, Sylvester R. Hormone therapy in prostatic cancer. Acta Urol Belg. 1980;48(1):98-105. [pmid: 7001876].
Smith PH, Armitage TG. Immediate versus deferred treatment for early prostatic cancer. Postgrad Med J. 1987;63(746):1055-60. [pmid: 3330236].
Smith PH, Bono A, Calais da Silva F, Debruyne F, Denis L, Robinson P, Sylvester R, Armitage TG. Some limitations of the radioisotope bone scan in patients with metastatic prostatic cancer. A subanalysis of EORTC trial 30853. The EORTC Urological Group. Cancer. 1990;66(5 Suppl):1009-16. [pmid: 2144203].
Smith PH, Pavone-Macaluso M, Viggiano G, de Voogt HD, Lardennois B, Robinson MR, Richards B, Glashan RW, de Pauw M, Sylvester R. EORTC protocols in prostatic cancer. Monogr Ser Eur Organ Res Treat Cancer. 1984;13:107-17.
Smith PH, Robinson MR. [Renaissance of estrogen therapy in advanced prostate carcinoma?]. Urologe A. 1995 Sep;34(5):393-7.
Soloway MS, Chodak G, Vogelzang NJ, Block NL, Schellhammer PF, Smith JA Jr, Scott M, Kennealey G, Gau TC. Zoladex versus orchiectomy in treatment of advanced prostate cancer: A randomized trial. Zoladex Prostate Study Group. Urology. 1991 Jan;37(1):46-51.
Soloway MS, Gomez CA. Patient selection for maximal androgen deprivation. Curr Opin Urol. 1993;3(5):388-93.
Soloway MS, Matzkin H. Antiandrogenic agents as monotherapy in advanced prostatic carcinoma. Cancer. 1993 Feb 1;71(3 Suppl):1083-8.
Soloway MS, Schellhammer P, Sharifi R, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. A controlled trial of Casodex (bicalutamide) vs. flutamide, each in combination with luteinising hormone-releasing hormone analogue therapy in patients with advanced prostate cancer. Casodex Combination Study Group. Eur Urol. 1996;29(Suppl 2):105-9. [pmid: 8717471].
Sonnenberg FA, Beck JR. Markov models in medical decision making: A practical guide. Med Decis Making. 1993 Oct;13(4):322-8.
Stamey TA, Kabalin JN. Prostate specific antigen in the diagnosis and treatment of adenocarcinoma of the prostate: I. Untreated patients. J Urol. 1989 May;141(5):1070-5.
Stanford JL, Stephenson RA, Coyle LM, Cerhan J, Correa R, Eley JW, Gilliland F, Hankey B, Kolonel LN, Kosary C, et al. Prostate Cancer Trends: 1973-1995, SEER Program, National Cancer Institute. Bethesda, MD; 1998.
Steg A. Problems of estrogen therapy in prostate cancer. J Urol (Paris). 1984;90(10):633-5.
Stege R, Carlstrom K, Eriksson A, Gustafsson SA, Henriksson P, Pousette A. Serum prolactin assays have no prognostic value in treatment of prostatic cancer by orchidectomy or estrogens. Urol Int. 1987;42(2):124-6. [pmid: 3617239].
Stone NN. Hormonal approaches in the treatment of bony metastases. Oncology (USA). 1994;8(11 Suppl):9-14. [pmcid: 419372].
Stone P, Phillips C,. Management of cancer of the prostate. N Engl J Med. 1995 Feb 2;332(5):335-6.
Studer UE. [Advanced prostatic carcinoma-which hormone therapy when?]. Urologe A. 1995 Sep;34(5):361-6. [pmid: 7483151].
Suciu S, Sylvester R, Iversen P, Christensen I, Denis L. Comparability of EORTC and DAPROCA studies in advanced prostatic cancer. Cancer. 1990 Sep 1;66(5 Suppl):1029-34.
Suciu S, Sylvester R, Iversen P, Christensen I, Denis L. Comparability of prostate trials. Cancer. 1993 Dec 15;72(12 Suppl):3841-6.
Swanson LJ, Garnick MB. Leuprolide versus diethylstilbestrol for metastatic prostatic cancer. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:301-8.
Takeuchi S, Yoshida K, Tosaka A, Kobayashi N, Higashi Y, Negishi T. [Study on prevention of flare-up phenomenon following initial LH-RH analogue administration: combination therapy with diethylstilbestrol]. Hinyokika Kiyo. 1995 Aug;41(3):191-6.
Tannock I, Osoba D. Quality of life: The appropriate measure of outcome for trials in metastatic prostatic cancer [abstract]. In: Workshop: Goals of Palliative Cancer Therapies; 1992 Mar 23-26; Reisensburg Castle, Germany; 1992.
Tannock IF, Osoba D, Stockler MR, Ernst DS, Neville AJ, Moore MJ, Armitage GR, Wilson JJ, Venner PM, Coppin CM, et al. Chemotherapy with mitoxantrone plus prednisone or prednisone alone for symptomatic hormone-resistant prostate cancer: A Canadian randomized trial with palliative end points. J Clin Oncol. 1996 Jun;14(6):1756-64.
TAP Pharmaceuticals, Inc. Lupron® (leuprolide acetate) injection prescribing information. Deerfield, IL; 1996 Apr.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 7.5 mg prescribing information. Deerfield, IL; 1997a Jun.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3 month (22.5 mg) prescribing information. Deerfield, IL; 1997b Mar.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 4 month (30 mg) prescribing information. Deerfield, IL; 1997c Jun.
TAP Pharmaceuticals, Inc. Lupron Depot-PED® (leuprolide acetate for depot suspension) prescribing information. Deerfield, IL; 1997d Mar.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3.75 mg prescribing information. Deerfield, IL; 1997e Apr.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3 month (11.25 mg) prescribing information. Deerfield, IL; 1997f Jul.
Taplin SH, Barlow W, Urban N, Mandelson MT, Timlin DJ, Ichikawa L, Nefcy P. Stage, age, comorbidity, and direct costs of colon, prostate, and breast cancer care. J Natl Cancer Inst. 1995 Mar 15;87(6):417-26.
Thall PF, Lachin JM. Assessment of stratum-covariate interactions in Cox's proportional hazards regression model. Stat Med. 1986 Jan;5(1):73-83.
The Canadian Anandron Study Group. Total androgen ablation in the treatment of metastatic prostatic cancer. Semin Urol. 1990 Aug;8(3):159-65.
The Leuprolide Study Group. Leuprolide versus diethylstilbestrol for metastatic prostate cancer. N Engl J Med. 1984 Nov 15;311(20):1281-6.
Theyer G, Holub S, Durer A, Andert S, Haberl I, Theyer U, Hamilton G. Measurements of tissue polypeptide-specific antigen and prostate-specific antigen in prostate cancer patients under intermittent androgen suppression therapy. Br J Cancer. 1997;75(10):1515-8. [pmid: 9166947].
Thorpe SC, Azmatullah S, Fellows GJ, Gingell JC, O'Boyle PJ. A prospective, randomised study to compare goserelin acetate (Zoladex) versus cyproterone acetate (Cyprostat) versus a combination of the two in the treatment of metastatic prostatic carcinoma. Eur Urol. 1996;29(1):47-54. [pmid: 8821690].
Thrasher JB, Crawford ED. Combined androgen blockade. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams & Wilkins; 1996. p. 875-84.
Toguchi H. Pharmaceutical manipulation of leuprorelin acetate to improve clinical performance. J Int Med Res. 1990;18(Suppl 1):35-41. [pmid: 2138986].
Tolis G, Koutsilieris M, Herrera R, Stellos A, Martinez A, Dufresne M. Advanced prostatic adenocarcinoma: Biological aspects and effects of androgen deprivation achieved by castration or agonistic analogues of LHRH. Med Oncol Tumor Pharmacother. 1984;1(2):129-36. [pmid: 6443576].
Trachtenberg J. Innovative approaches to the hormonal treatment of advanced prostate cancer. Eur Urol. 1997;32(Suppl 3):78-80. [pmid: 9267790].
Trachtenberg J. Progress in complete androgen blockade. Eur Urol. 1997;31(Suppl 2):8-10. [pmid: 9074904].
Tunn UW. Cyproterone acetate in the management of prostatic cancer. Prog Clin Biol Res. 1989;303:105-10. [pmid: 2528734].
Tunn UW, Weiglein W, Saborowski J, Senge T. Clinical experience with cyproterone acetate in a randomised and in an open trial. Prog Clin Biol Res. 1987;243A:365-8. [pmid: 2958860].
Turkes AO, Griffiths K. Endocrine treatment of prostate cancer. Prog Med Chem. 1989;26:299-321. [pmid: 2532376].
Turkes AO, Peeling WB, Griffiths K. Treatment of patients with advanced cancer of the prostate: Phase III trial, Zoladex against castration; a study of the British Prostate Group. J Steroid Biochem. 1987;27(1-3):543-9. [pmid: 2961938].
Tyrrell CJ. Tolerability and quality of life aspects with the anti-androgen Casodex (ICI 176,334) as monotherapy for prostate cancer. International Casodex Investigators. Eur Urol. 1994;26(Suppl 1):15-9. [pmid: 7537664].
Tyrrell CJ, Altwein JE, Klippel F, Varenhorst E, Lunglmayr G, Boccardo F, Holdaway IM, Haefliger JM, Jordaan JP. A multicenter randomized trial comparing the luteinizing hormone-releasing hormone analogue goserelin acetate alone and with flutamide in the treatment of advanced prostate cancer. The International Prostate Cancer Study Group. J Urol. 1991 Nov;146(5):1321-6.
Tyrrell CJ, Altwein JE, Klippel F, Varenhorst E, Lunglmayr G, Boccardo F, Holdaway IM, Haefliger JM, Jordaan JP, Sotarauta M. Multicenter randomized trial comparing Zoladex with Zoladex plus flutamide in the treatment of advanced prostate cancer. Survival update. International Prostate Cancer Study Group. Cancer. 1993 Dec 15;72(12 Suppl):3878-9.
Usami M, Kotake T, Matsuda M, Okajima E, Osafune M, Akaza H, Nihsijima T, Aso Y, Araki T, Itatani H, et al. [Clinical efficacy of long-term treatment with LH-RH analogue, ICI 118630 (Zoladex), in prostatic cancer patients. The Zoladex Multicenter Study Group]. Hinyokika Kiyo. 1988 Nov;34(11):2059-66.
Usami M, Kotake T, Matsuda M, Okajima E, Osafune M, Akaza H, Niijima T, Aso Y, Araki T, Itatani H, et al. [Endocrine therapy for prostatic carcinoma-the clinical trial to compare the efficacy of LH-RH analogue, ICI 118630 (Zoladex) with castration or estrogen]. Hinyokika Kiyo. 1988 Oct;34(10):1853-63.
Van Poppel H, Ameye F, Oyen R, Van De Voorde W, Baert L. Neo-adjuvant hormonotherapy does not facilitate radical prostatectomy. Acta Urol Belg. 1992;60(3):73-82.
Veterans Administration Cooperative Urological Research Group. Carcinoma of the prostate: Treatment comparisons. J Urol. 1967;98(4):516-22. [pmid: 4862213].
Veterans Administration Cooperative Urological Research Group. Treatment and survival of patients with cancer of the prostate. Surg Gynecol Obstet. 1967 May;124(5):1011-7.
Vogelzang NJ. New developments in the treatment of advanced prostate cancer: Proceedings from a roundtable workshop held May 22, 1996, in Philadelphia, PA. Semin Oncol. 1996;23(6 Suppl 14):1-5.
Vogelzang NJ, Chodak GW, Soloway MS, Block NL, Schellhammer PF, Smith JA Jr, Caplan RJ, Kennealey GT. Goserelin versus orchiectomy in the treatment of advanced prostate cancer: Final results of a randomized trial. Zoladex Prostate Study Group. Urology. 1995 Aug;46(2):220-6. [pmcid: 434513].
Vogelzang NJ, Kennealey GT. Recent developments in endocrine treatment of prostate cancer. Cancer. 1992 Aug 15;70(4 Suppl):966-76.
Vogelzang NJ, Schellhammer PF, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Jones JA, Kennealey GT. A randomized double-blind trial in 813 previously untreated metastatic prostate cancer (CAP) patients (PTS) comparing a new antiandrogen Casodex (bicalutamide) with Eulexin (flutamide) in combination with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Voges GE, Mottrie AM, Stockle M, Muller SC. Hormone therapy prior to radical prostatectomy in patients with clinical stage C prostate cancer. Prostate Suppl. 1994;5:4-8. [pmid: 7513531].
Walsh PC. Immediate versus deferred treatment for advanced prostate cancer: initial results of the Medical Research Council trial. The Medical Research Council Prostate Cancer Working Party Investigators Group. J Urol. 1997 Oct;158(4):1623-4.
Wang Y, Fair WR. Neoadjuvant hormonal therapy in prostate cancer. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 561-5.
Waxman J. A review of the Hammersmith Hospital, St. Bartholomew's Hospital, and Institute of Urology studies of buserelin in advanced prostatic cancer. Am J Clin Oncol. 1988;11(Suppl 1):S16-S18. [pmid: 3133943].
Waxman J. Short-term anti-androgen therapy and very long-acting depot gonadotrophin-releasing hormone agonist for prostatic cancer. Prog Clin Biol Res. 1989;303:61-8. [pmid: 2528741].
Waxman J. What is the correct hormonal treatment for prostate cancer?. Eur J Cancer. 1993;29(8):1075-6. [pmid: 8518015].
Waxman J, Man A, Hendry WF, Whitfield HN, Besser GM, Tiptaft RC, Paris AM, Oliver RT. Importance of early tumour exacerbation in patients treated with long acting analogues of gonadotrophin releasing hormone for advanced prostatic cancer. BMJ (Clin Res Ed). 1985;291(6506):1387-8. [pmcid: 117638].
Waxman J, Pandha H. Do we know what's best for prostate cancer?. Eur J Cancer. 1996 Aug;32A(9):1455-6.
Waxman J, Pandha H,. Anti-androgens in treatment of prostate cancer. Lancet. 1995 Oct 14;346(8981):1030-2.
Waxman J, Williams G, Sandow J, Hewitt G, Abel P, Farah N, Fleming J, Cox J, O'Donoghue EP, Sikora K. The clinical and endocrine assessment of three different antiandrogen regimens combined with a very long-acting gonadotrophin-releasing hormone analogue. Am J Clin Oncol. 1988;11(Suppl 2):S152-S155. [pmid: 2853934].
Waxman S, Crawford ED. Endocrine therapy of advanced carcinoma of the prostate. Endocrine Rel Cancer. 1996;3(3):279-83.
Waymont B, Lynch TH, Dunn JA, Emtage LA, Arkell DG, Wallace DM, Blackledge GR. Phase III randomised study of Zoladex versus stilboestrol in the treatment of advanced prostate cancer. Br J Urol. 1992 Jun;69(6):614-20.
Wechsel HW, Zerbib M, Pagano F, Coptcoat MJ. Randomized open labelled comparative study of the efficacy, safety and tolerability of leuprorelin acetate 1M and 3M depot in patients with advanced prostatic cancer. Eur Urol. 1996;30(Suppl 1):7-14. [pmid: 8977984].
Whitehead A, Whitehead J. A general approach to the meta-analysis of randomized clinical trials. Stat Med. 1991 Nov;10(11):1665-77.
Williams G, Asopa R, Abel PD, Smith C. Pituitary adrenal and gonadal endocrine suppression for the primary treatment of prostate cancer. Br J Urol. 1990 May;65(5):504-8.
Williams G, Kiely E A, Kapadia R, Doble A, Ware H, Timoney A. A study of the role of additional androgen depletion for primary therapy of patients with advanced local or metastatic carcinoma of the prostate. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:119-25.
Winfield H, Trachtenberg J. A comparison of a powerful luteinizing hormone releasing hormone analogue agonist and estrogen in the treatment of advanced prostatic cancer. J Urol. 1984;131(6):1107-9. [pmid: 6427477].
Winkel CA. Gonadotropin-releasing hormone agonists. Current uses for these increasingly important drugs. Postgrad Med. 1994;95(6):111-8. [pmid: 8170869].
Wojciechowski NJ, Carter CA, Skoutakis VA, Bess DT, Falbe WJ, Mickle TR. Leuprolide: A gonadotropin-releasing hormone analog for the palliative treatment of prostatic cancer. Drug Intell Clin Pharm. 1986;20:746-51. [pmid: 2429815].
Wollin M, Diamond DA,Menon M. Hormonal therapy for advanced carcinoma of the prostate. In: Williams RD, editor. Advances in Urologic Oncology. Vol. 1. General Perspectives. New York: Macmillan Publishing Company; 1987. p. 131-62.
Woolf SH. Screening for prostate cancer with prostate-specific antigen. An examination of the evidence. N Engl J Med. 1995 Nov 23;333(21):1401-5. [pmid: 7477122].
Wysowski DK, Fourcroy JL. Safety of flutamide?. Fertil Steril. 1994 Nov;62(5):1089-1090.
Wysowski DK, Fourcroy JL. Flutamide hepatotoxicity. J Urol. 1996 Jan;155(1):209-12.
Young HH 2d, Kent JR. Plasma testosterone levels in patients with prostatic carcinoma before and after treatment. J Urol. 1968;99(6):788-92. [pmid: 4871357].
Zagars GK, Johnson DE, von Eschenbach AC, Hussey DH. Adjuvant estrogen following radiation therapy for stage C adenocarcinoma of the prostate: Long-term results of a prospective randomized study. Int J Radiat Oncol Biol Phys. 1988 Jun;14(6):1085-91.
Zalcberg JR, Raghaven D, Marshall V, Thompson PJ. Bilateral orchidectomy and flutamide versus orchidectomy alone in newly diagnosed patients with metastatic carcinoma of the prostate-an Australian multicentre trial. Br J Urol. 1996 Jun;77(6):865-9.
Zeneca Pharmaceuticals. Casodex® (bicalutamide) tablets prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1997 Jan. p. 3151-3.
Zeneca Pharmaceuticals. Zoladex® 3.6 mg (goserelin acetate) implant prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1996a Apr. p. 3194-6.
Zeneca Pharmaceuticals. Zoladex® 3-month (goserelin acetate) implant 10.8 mg prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1996b Apr. p. 3196-8.
Zerbib M, Lucas C, Leblanc V. [Effectiveness and tolerance of three month sustained release leuprorelin in the treatment of metastatic prostatic cancer (comparative, randomized, multicentric study]. Prog Urol. 1997 Apr;7(2):246-53.
Zerbib M, Payan C. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer [letter]. Urology. 1996 Oct;48(4):661-3. [pmcid: 140032].
Zietman AL, Dallow KC, McManus PA, Heney NM, Shipley WU. Time to second prostate-specific antigen failure is a surrogate endpoint for prostate cancer death in a prospective trial of therapy for localized disease. Urology. 1996 Feb;47(2):236-9.
Zietman AL, Prince EA, Nakfoor BM, Shipley WU. Neoadjuvant androgen suppression with radiation in the management of locally advanced adenocarcinoma of the prostate: experimental and clinical results. Urology. 1997 Mar;49(Suppl 3A):74-83. [pmcid: 140032].
Zietman AL. The role of radiation as adjuvant or salvage therapy following radical prostatectomy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 782-90.
Zimel H, Bocancea D. Treatment of prostatic carcinoma with Stilbostat. Neoplasma. 1974;21(1):101-8. [pmid: 4596007].