# References

Atala A, Amin M. Current concepts in the treatment of genitourinary tract disorders in the older individual. Drugs Aging. 1991 May;1(3):176-93.
Balducci L, Pow-Sang J, Friedland J, Diaz JI. Prostate cancer. Clin Geriatr Med. 1997 May;13(2):283-306.
Bales GT, Chodak GW. A controlled trial of bicalutamide versus castration in patients with advanced prostate cancer. Urology. 1996 Jan;47(1A Suppl):38-43.
Barradell LB, Faulds D. Cyproterone.A review of its pharmacology and therapeutic efficacy in prostate cancer. Drugs Aging. 1994 Jul;5(1):59-80.
Beck JR, Pauker SG. The Markov process in medical prognosis. Med Decis Making. 1983;3(4):419-58. [pmid: 6668990].
Beland G. Combination of Anandron with orchiectomy in treatment of metastatic prostate cancer. Results of a double-blind study. Urology. 1991;37(2 Suppl):25-9. [pmid: 1992600].
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Venner PM, Tewari HD. Total androgen blockade vs orchiectomy in stage D2 prostate cancer. Prog Clin Biol Res. 1987;243A:391-400. [pmid: 3116550].
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM. Total androgen blockade for metastatic cancer of the prostate. Am J Clin Oncol. 1988;11(Suppl 2):S187-S190. [pmid: 3149456].
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM, Tewari HD. A controlled trial of castration with and without nilutamide in metastatic prostatic carcinoma. Cancer. 1990a Sep 1;66(5 Suppl):1074-9.
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey E, Trachtenberg J, Tewari H, Venner P. Total androgen ablation versus castration in the treatment of metastatic prostatic cancer [abstract]. In: International Testicular and Prostatic Cancer Conference, 1990 Oct 4-6; Toronto, Canada; 1990c. p. 92.
Beland G, Elhilali M, Fradet Y, Laroche B, Ramsey EW, Trachtenberg J, Venner PM, Tewari HD. Total androgen ablation: Canadian experience. Urol Clin North Am. 1991 Feb;18(1):75-82.
Bennett CL, Matchar D, McCrory D, McLeod DG, Crawford ED, Hillner BE. Cost-effective models for flutamide for prostate carcinoma patients: are they helpful to policy makers?. Cancer. 1996 May 1;77(9):1854-61.
Benson RC. Total androgen blockade: The United States experience. Eur Urol. 1993;24(Suppl 2):72-6. [pmid: 8262130].
Benson RC Jr, Crawford ED, Eisenberger MA, McLeod DG, Spaulding JT, Dorr FA. National Cancer Institute study of luteinizing hormone-releasing hormone plus flutamide versus luteinizing hormone-releasing hormone plus placebo. Semin Oncol. 1991 Oct;18(5 Suppl 6):9-12.
Bertagna C, De Gery A, Hucher M, Francois JP, Zanirato J. Efficacy of the combination of nilutamide plus orchidectomy in patients with metastatic prostatic cancer. A meta-analysis of seven randomized double-blind trials (1056 patients). Br J Urol. 1994 Apr;73(4):396-402.
Bischoff W. 3.75 and 7.5 mg leuprorelin acetate depot in the treatment of advanced prostatic cancer: Preliminary report. German Leuprorelin Study Group. J Int Med Res. 1990;18(Suppl 1):103-13. [pmid: 2108882].
Black WC, Nease RF, Welch G. Determining transition probabilities from mortality rates and autopsy findings. Med Decis Making. 1997 Jan;17(1):87-93.
Blackard CE, Byar DP, Jordan WP Jr. Orchiectomy for advanced prostatic carcinoma. A reevaluation. Urology. 1973 Jun;1(6):553-60. [pmcid: 111060].
Blackledge G, Kolvenbag G, Nash A. Bicalutamide: A new antiandrogen for use in combination with castration for patients with advanced prostate cancer. Anticancer Drugs. 1996 Jan;7(1):27-34.
Blackledge GR. Clinical progress with a new antiandrogen, Casodex (bicalutamide). Eur Urol. 1996;29(Suppl 2):96-104. [pmid: 8717470].
Blue Cross and Blue Shield Association. Brachytherapy for prostate cancer. Technology Evaluation Center (TEC) Assessment Program. 1997 June;12(5):1-28. [pmcid: 169025].
Boccardo F, Pace M, Rubagotti A, Guarneri D, Decensi A, Oneto F, Martorana G, Giuliani L, Selvaggi F, Battaglia M, et al. Goserelin acetate with or without flutamide in the treatment of patients with locally advanced or metastatic prostate cancer. The Italian Prostatic Cancer Project (PONCAP) Study Group. Eur J Cancer. 1993;29A(8):1088-93. [pmid: 8518017].
Boccon-Gibod L, Fournier G, Bottet P, Marechal JM, Guiter J, Rischman P, Hubert J, Soret JY, Mangin P, Mallo C, et al. Flutamide versus orchidectomy in the treatment of metastatic prostate carcinoma. Eur Urol. 1997;32(4):391-5. [pmid: 9412794].
Bolla M, Bartelink H, Gibbons R, Gospodarowicz M, Hanks G, Kakizoe T, Meyhoff H, Prezioso D, Senge T, Schearer R. Treatment of regional disease. In: Murphy G, Griffiths K, Denis L, Khoury S, Chatelain C, Cockett AT, editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 259-66.
Bolla M, Gonzalez D, Warde P, Dubois JB, Mirimanoff R-O, Storme G, Bernier J, Kuten A, Sternberg C, Gil T, et al. Improved survival in patients with locally advanced prostate cancer treated with radiotherapy and goserelin. N Engl J Med. 1997 Jul 31;337(5):295-300.
Bono AV, DiSilverio F, Robustelli della Cuna G, Benvenuti C, Brausi M, Ferrari P, Gibba A, Galli L. Complete androgen blockade versus chemical castration in advanced prostatic cancer: Analysis of an Italian multicentre study. Italian Leuprorelin Group. Urol Int. 1998;60(Suppl 1):18-24.
Boyle P, Napalkov P, Barry MJ, Bishop DT, Correa R, Gu F-L, Guess H, Jacobsen S, Kiemeney LA, Nagy G, et al. Epidemiology and natural history of prostate cancer. In: Murphy G, Griffiths K, Denis L, Khoury S, Chatelain C, Cockett AT, editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 1-29.
Brisset JM, Boccon-Gibod L, Botto H, Camey M, Cariou G, Duclos J M, Duval F, Gonties D, Jorest R, Lamy L, et al. Anandron (RU 23908) associated to surgical castration in previously untreated stage D prostate cancer: a multicenter comparative study of two doses of the drug and of a placebo. Prog Clin Biol Res. 1987;243A:411-22. [pmid: 3309973].
Brogden RN, Clissold SP. Flutamide. A preliminary review of its pharmacodynamic and pharmacokinetic properties, and therapeutic efficacy in advanced prostatic cancer. Drugs. 1989 Aug;38(2):185-203.
Brogden RN, Buckley MM, Ward A. Buserelin. A review of its pharmacodynamic and pharmacokinetic properties, and clinical profile. Drugs. 1990 Mar;39(3):399-437.
Bruun E, Frimodt-Moller C for the Danish Buserelin Study Group. The effect of buserelin versus conventional antiandrogenic treatment in patients with T2-4NXM1 prostatic cancer: A prospective, randomized multicentre phase III trial. Scand J Urol Nephrol. 1996 Aug;30(4):291-7.
Bubley GJ, Balk SP. Treatment of metastatic prostate cancer. Lessons from the androgen receptor. Hematol Oncol Clin North Am. 1996 Jun;10(3):713-25.
Byar DP. Proceedings: The Veterans Administration Cooperative Urological Research Group's studies of cancer of the prostate. Cancer. 1973 Nov;32(5):1126-30. [pmid: 4585929].
Byar D, Corle DK. Hormone therapy for prostate cancer: results of the Veterans Administration Cooperative Urologic Research Group studies. Natl Cancer Inst Monogr. 1988;7.
Cantor S. Cost-effectiveness analysis, extended dominance and ethics: A quantitative assessment. Med Decis Making. 1994;14:259-65. [pmid: 7934713].
Carvalho AP, de Moura JL, Denis L, Newling D, Smith P, Bono A, Sylvester R, De Pauw M, Ongena P. Zoladex and flutamide vs orchidectomy: A phase III EORTC 30853 trial. EORTC Urological Group. Prog Clin Biol Res. 1989;303:129-43. [pmid: 2528736].
Cassileth BR, Soloway MS, Vogelzang NJ, Chou JM, Schellhammer PD, Seidmon EJ, Kennealey GT. Quality of life and psychosocial status in stage d prostate cancer. Qual Life Res. 1992;1(5):323-30. [pmid: 1299464].
Caubet JF, Tosteson TD, Dong EW, Naylon EM, Whiting GW, Ernstoff MS, Ross SD. Maximum androgen blockade in advanced prostate cancer: A meta-analysis of published randomized controlled trials using nonsteroidal antiandrogens. Urology. 1997 Jan;49(1):71-8. [pmcid: 140032].
Chalmers TC, Smith H Jr, Blackburn B, Silverman B, Schroeder B, Reitman D, Ambroz A. A method for assessing the quality of a randomized control trial. Controlled Clin Trials. 1981 May;2(1):31-49.
Chang A, Yeap B, Blum R, Hahn R, Khanna O, Fisher H, Witte R, Trump D. A double-blind randomized study of primary treatment for stage D2 prostate cancer: Diethylstilbestrol (DES) vs flutamide(F) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1992;11.
Chang A, Yeap B, Davis T, Blum R, Hahn R, Khanna O, Fisher H, Rosenthal J, Witte R, Schinella R, et al. Double-blind, randomized study of primary hormonal treatment of stage D2 prostate carcinoma: Flutamide versus diethylstilbestrol. J Clin Oncol. 1996 Aug;14(8):2250-7.
Chodak G, Sharifi R, Kasimis B, Block NL, Macramalla E, Kennealey GT. Single-agent therapy with bicalutamide: A comparison with medical or surgical castration in the treatment of advanced prostate carcinoma. Urology. 1995 Dec;46(6):849-55. [pmcid: 434513].
Chrisp P, Goa KL. Goserelin. A review of its pharmacodynamic and pharmacokinetic properties, and clinical use in sex hormone-related conditions. Drugs. 1991 Feb;41(2):254-88.
Chrisp P, Sorkin EM. Leuprorelin. A review of its pharmacology and therapeutic use in prostatic disorders. Drugs Aging. 1991 Nov;1(6):487-509.
Christensen MM, Aagaard J, Madsen PO. Reasons for delay of endocrine treatment in cancer of the prostate (until symptomatic metastases occur). Prog Clin Biol Res. 1990;359:7-14. [pmid: 2284298].
Citrin DL, Resnick MI, Guinan P, al-Bussam N, Scott M, Gau TC, Kennealey GT. A comparison of Zoladex and DES in the treatment of advanced prostate cancer: Results of a randomized, multicenter trial. Prostate. 1991;18(2):139-46. [pmid: 1826048].
Cleary PD, Morrissey G, Oster G. Health-related quality of life in patients with advanced prostate cancer: A multinational perspective. Qual Life Res. 1995 Jun;4(3):207-20.
Coley CM, Barry MJ, Fleming C, Mulley AG. Early detection of prostate cancer. Part 1. Prior probability and effectiveness of tests. Ann Intern Med. 1997a Mar 1;126(5):394-406.
Coley CM, Barry MJ, Fleming C, Fahs MC. Early detection of prostate cancer. Part 2. Estimating the risks, benefits, and costs. Ann Intern Med. 1997b Mar 15;126(6):468-79.
Conn PM, Crowley WF Jr. Gonadotropin-releasing hormone and its analogues. N Engl J Med. 1991 Jan 10;324(2):93-103.
Cooper HM, Hedges LV, editors. The handbook of research synthesis. New York: The Russell Sage Foundation; 1994.
Corn BW, Hanks GE. Management of stage C (T3) prostate cancer: radiotherapy. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 541-52.
Cowen ME, Chartrand M, Weitzel WF. A Markov model of the natural history of prostate cancer. J Clin Epidemiol. 1994 Jan;47(1):3-21.
Crawford ED. Combination studies with leuprolide. Eur Urol. 1990a;18(Suppl 3):30-3. [pmid: 2128828].
Crawford ED. Total androgen blockade: The NCI study [abstract]. In: International Testicular and Prostatic Cancer Conference. 1990 Oct 4-6; Toronto, Canada. 1990b. p. 91.
Crawford ED. Changing concepts in the management of advanced prostate cancer. Urology. 1994;44(6 Suppl.):67-74.
Crawford ED. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer [letter; comment]. Urology. 1995 Dec;46(6):899-901. [pmcid: 434513].
Crawford ED, Allen JA. Treatment of newly diagnosed state D2 prostate cancer with leuprolide and flutamide or leuprolide alone, phase III, intergroup study 0036. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):961-3.
Crawford ED, Nabors WL. Total androgen ablation: American experience. Urol Clin North Am. 1991 Feb;18(1):55-63.
Crawford ED, Goodman P, Blumenstein B. Combined androgen blockade: Leuprolide and flutamide versus leuprolide and placebo. Semin Urol. 1990 Aug;8(3):154-8.
Crawford ED, Blumenstein BA, Goodman PJ, Davis MA, Eisenberger MA, McLeod DG, Spaulding JT, Benson R, Dorr FA. Leuprolide with and without flutamide in advanced prostate cancer. Cancer. 1990 Sep 1;66(5 Suppl):1039-44.
Crawford ED, Eisenberger MA, McLeod DG, Spaulding JT, Benson R, Dorr FA, Blumenstein BA, Davis MA, Goodman PJ. A controlled trial of leuprolide with and without flutamide in prostatic carcinoma. N Engl J Med. 1989 Aug 17;321(7):419-24.
Crawford ED, Fourcade RO, Iversen P, et al. Management of newly diagnosed, metastatic prostate cancer. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 267-303.
Crawford ED, Kasimis BS, Gandara D, Smith JA, Soloway MS, Lange PH, Lynch DF, Al-Juburi A, Bracken RB, Wise HA, et al. A randomized, controlled clinical trial of leuprolide and anandron (LA) vs leuprolide and placebo (LP) for advanced prostate cancer (D2cap) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1990;9.
da Silva FC. Quality of life in prostatic cancer patients. Cancer. 1993 Dec 15;72(12 Suppl):3803-6. [pmid: 8252494].
da Silva FC, Aaronson N. Quality of life assessment in prostatic cancer. Prog Clin Biol Res. 1988;260:119-21. [pmid: 2966404].
da Silva FC, Fossa SD, Aaronson NK, Serbouti S, Denis L, Casselman J, Whelan P, Hetherington J, Fava C, Richards B, Robinson MR. The quality of life of patients with newly diagnosed M1 prostate cancer: Experience with EORTC clinical trial 30853. Eur J Cancer. 1996 Jan;32A(1):72-7.
da Silva FC, Reis E, Costa T, Denis L. Quality of life in patients with prostatic cancer. A feasibility study. The Members of Quality of Life Committee of the EORTC Genitourinary Group. Cancer. 1993 Feb 1;71(3 Suppl):1138-42.
Daniell HW. Osteoporosis after orchiectomy for prostate cancer. J Urol. 1997 Feb;157(2):439-44. [pmid: 8996327].
Decensi A, Guarneri D, Paoletti MC, Lalanne JM, Merlo F, Boccardo F. Phase II study of the pure non-steroidal antiandrogen nilutamide in prostatic cancer. Italian Prostatic Cancer Project (PONCAP). Eur J Cancer. 1991;27(9):1100-4. [pmid: 1835617].
Fernandez del Moral PF, Dijkman GA, Debruyne FMJ, Witjes WPJ, Kolvenbag GJCM, van der Meijden APM, Plasman JWMH, Pull HC, Kums JJ, Idema JG, et al. Three-month depot of goserelin acetate: Clinical efficacy and endocrine profile. Urology. 1996;48(6):894-900. [pmcid: 140032]. [pmid: 8973673].
de Voogt HJ. Cyproterone acetate as monotherapy in prospective randomized trials. Prog Clin Biol Res. 1990;359:85-91. [pmid: 2149459].
de Voogt HJ, Klijn JG, Studer U, Schroder F, Sylvester R, De Pauw M. Orchidectomy versus Buserelin in combination with cyproterone acetate, for 2 weeks or continuously, in the treatment of metastatic prostatic cancer. Preliminary results of EORTC-trial 30843. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):965-9.
de Voogt HJ, Smith PH, Pavone-Macaluso M, de Pauw M, Suciu S. Cardiovascular side effects of diethylstilbestrol, cyproterone acetate, medroxyprogesterone acetate and estramustine phosphate used for the treatment of advanced prostatic cancer: Results from European Organization for Research on Treatment of Cancer trials 30761 and 30762. J Urol. 1986 Feb;135(2):303-7.
Debruyne FM. Combined androgen blockade is the treatment of choice for patients with advanced prostate cancer: The argument for. Eur Urol. 1996;29(Suppl 2):34-6. [pmid: 8717460].
Debruyne FMJ, Dijkman GA. Advances and trends in hormonal therapy for advanced prostate cancer. Eur Urol. 1995;28(3):177-88. [pmid: 8536770].
Dempster AD, Laird NM, Rubin DB. Maximum likelihood from incomplete data via the EM algorithm. J Royal Stat Soc B. 1977;38:1-22.
Denis L. Prostate cancer. Primary hormonal treatment. Cancer. 1993 Feb 1;71(3 Suppl):1050-8. [pmid: 8428327].
Denis L. Commentary on maximal androgen blockade in prostate cancer: a theory to put into practice?. Prostate. 1995 Nov;27(5):233-40. [pmid: 7479390].
Denis LJ, Carnelro de Moura JL, Bono A, Sylvester R, Whelan P, Newling D, Depauw M. Goserelin acetate and flutamide versus bilateral orchiectomy: A phase III EORTC trial (30853). EORTC GU Group and EORTC Data Center. Urology. 1993 Aug;42(2):119-29. [pmcid: 434513].
Denis L, Keuppens F, Newling D, Smith P H, Calais da Silva F, Sylvester R, DePauw M, Onegana P and Members of the EORTC-GU Group Belgium. Orchidectomy versus total androgen blockade: A phase III EORTC 30853 study. GnRH Analogues Cancer Human Reproduction. 1990;3:117-27.
Denis L, Keuppens F, Robinson M, Mahler C, Smith P, Pinto de Carvalho AP, Newling D, Bono A, Sylvester R, De Pauw M, et al. Complete androgen blockade: Data from an EORTC 30853 trial. Semin Urol. 1990 Aug;8(3):166-74.
Denis L, Robinson M, Mahler C, Smith P, Keuppens F, De Moura JL, Bono A, Newling D, Sylvester R, De Pauw M, et al. Orchidectomy versus Zoladex plus Eulexin in patients with metastatic prostate cancer (EORTC 30853). J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):951-9.
Denis L, Smith P, Carneiro de Moura JL, Newling D, Bono A, Keuppens F, Mahler C, Robinson M, Sylvester R, De Pauw M, et al. Total androgen ablation: European experience. The EORTC GU Group. Urol Clin North Am. 1991 Feb;18(1):65-73.
Denis L, Smith PH, De Moura JL, Newling DW, Bono A, Keuppens F, Robinson M, Mahler C, Sylvester R, De Pauw M, et al. Orchidectomy vs. Zoladex plus flutamide in patients with metastatic prostate cancer. The EORTC GU Group. Eur Urol. 1990;18(Suppl 3):34-40. [pmid: 2151274].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
Di Silverio F, Serio M. [Zoladex in prostatic carcinoma]. Drugs Exp Clin Res. 1990;16(Suppl):19-29. [pmid: 2150501].
Di Silverio F, Serio M, D'Eramo G, Sciarra F. Zoladex vs. Zoladex plus cyproterone acetate in the treatment of advanced prostatic cancer: A multicenter Italian study. Eur Urol. 1990;18(Suppl 3):54-61. [pmid: 2151278].
Dijkman GA, Fernandez del Moral P, Debruyne FM, Janknegt RA. Improved subjective responses to orchiectomy plus nilutamide (Anandron) in comparison to orchiectomy plus placebo in metastatic prostate cancer. International Anandron Study Group. Eur Urol. 1995;27(3):196-201. [pmid: 7601182].
Dijkman GA, Janknegt RA, De Reijke TM, Debruyne FM. Long-term efficacy and safety of nilutamide plus castration in advanced prostate cancer, and the significance of early prostate specific antigen normalization. International Anandron Study Group. J Urol. 1997 Jul;158(1):160-3.
Drug Topics Red Book. Montvale, NJ: Medical Economics; 1997.
Eisenberger MA, Blumenstein BA, Crawford ED, Miller G, McLeod DG, Loehrer PJ, Wilding G, Sears K, Culkin DJ, Thompson IM Jr, et al. Bilateral orchiectomy with or without flutamide for prostate cancer. N Engl J Med. 1998;339(15):1036-42. [pmid: 9761805].
Eisenberger M, Crawford ED, McLeod D, Loehrer P, Wilding G, Blumenstein B. A comparison of bilateral orchiectomy (orch) with or without flutamide in stage D2 prostate cancer (PC) (NCI INT-0105 SWOG/ECOG). Proc Annu Meet Am Soc Clin Oncol. 1997;16.
Eisenberger M, Crawford ED, McCleod D, Benson R, Dorr A, Blumenstein B. A comparison of leuprolide and flutamide vs leuprolide alone in newly diagnosed stage D2 prostate cancer: Prognostic and therapeutic importance of the minimal disease subset [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1992;11.
Eisenberger MA, Crawford ED, Wolf M, Blumenstein B, McLeod DG, Benson R, Dorr FA, Benson M, Spaulding JT. Prognostic factors in stage D2 prostate cancer; important implications for future trials: Results of a Cooperative Intergroup Study (Int.0036). The National Cancer Institute Intergroup Study #0036. Semin Oncol. 1994;21(5):613-9. [pmid: 7939752].
Emtage LA, Trethowan C, Hilton C, Kelly K, Blackledge GR. Interim report of a randomized trial comparing Zoladex 3.6 mg depot with diethylstilbestrol 3 mg/day in advanced prostate cancer. The West Midlands Urology Research Group. Am J Clin Oncol. 1988;11(Suppl 2):S173-S175. [pmid: 2977273].
Emtage LA, Trethowan C, Kelly K, Arkell D, Wallace DM, Hughes M, Hay A, Blacklock R, Jones M, Rouse A, et al. A phase III open randomized study of Zoladex 3.6 mg depot vs. DES 3 mg per day in untreated advanced prostate cancer: A West Midlands Urological Research Group Study. Prog Clin Biol Res. 1989;303:47-52. [pmid: 2528739].
Epstein JI, Walsh PC, Brendler CB. Radical prostatectomy for impalpable prostate cancer: The Johns Hopkins experience with tumours found on transurethral resection (stages T1A and T1B) and on needle biopsy. J Urol. 1994 Nov;152(5 Pt 2):1721-9.
European Organization for Research and Treatment of Cancer (EORTC). Practical Guidelines for Clinical Studies. Brussels: European Organization for Research and Treatment of Cancer; 1996.
Ferrari P, Castagnetti G, Ferrari G, Pollastri CA, Tavoni F, Dotti A. Combination treatment in M1 prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3880-5.
Ferrari P, Castagnetti G, Ferrari G, Baisi B, Dotti A. Combination treatment versus LHRH alone in advanced prostatic cancer. Urol Int. 1996;56(Suppl 1):13-7.
Fitzpatrick JM. Combined androgen blockade is the treatment of choice for patients with advanced prostate cancer: the argument against. Eur Urol. 1996;29(Suppl 2):37-9. [pmid: 8717461].
Fleming C, Wasson JH, Albertsen PC, Barry MJ, Wennberg JE. A decision analysis of alternative treatment strategies for clinically localized prostate cancer. Prostate Patient Outcomes Research Team. JAMA. 1993 May 26;269(20):2650-8.
Fourcade RO, Cariou G, Coloby P, Colombel P, Coulange C, Grise P, Mangin P, Soret JY, Poterre M. Total androgen blockade with Zoladex plus flutamide vs. Zoladex alone in advanced prostatic carcinoma: Interim report of a multicenter, double-blind, placebo-controlled study. Eur Urol. 1990;18(Suppl 3):45-7.
Frazier HA, Robertson JE, Humphrey PA, Paulson DF. Is prostate specific antigen of clinical importance in evaluating outcome after radical prostatectomy. J Urol. 1993 Mar;149(3):516-8.
Frydenberg M, Oesterling JE. Management of stage C (T3) prostate cancer: Nonradiation therapy. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 535-41.
Gann PH, Hennekens CH, Stampfer MJ. A prospective evaluation of plasma prostate-specific antigen for detection of prostatic cancer. JAMA. 1995 Jan 25;273(4):289-94.
Garnick MB. Leuprolide versus diethylstilbestrol for previously untreated stage D2 prostate cancer. Results of a prospectively randomized trial. Urology. 1986 Jan;27(1 Suppl):21-8. [pmid: 3079935].
Garnick MB. Hormonal therapy in the management of prostate cancer: from Huggins to the present. Urology. 1997 Mar;49(Suppl 3A):5-15. [pmcid: 140032]. [pmid: 9123737].
Garnick MB, Glode LM, Smith JA Jr, Max DT. Leuprolide: A review of its effects in comparison with diethylstilboestrol in the treatment of advanced cancer of the prostate. Br J Clin Pract. 1985a Feb;39(2):73-6.
Garnick MB, Glode LM, Smith JA Jr, Max DT. Leuprolide: A review of its effects in comparison with diethylstilboestrol in the treatment of advanced cancer of the prostate. Br J Clin Pract Symp Suppl. 1985b Mar;37:8-12, 20-4. [pmid: 3931665].
Gold MR, Seigel JE, Russell LB, et al., editors. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Goldenberg SL, Bruchovsky N. Androgen withdrawal therapy: New perspectives in the treatment of prostate cancer. In: Rhagavan D, Scher RI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 583-91.
Goldenberg SL, Bruchovsky N, Gleave ME, Sullivan LD, Akakura K. Intermittent androgen suppression in the treatment of prostate cancer: A preliminary report. Urology. 1995 May;45(5):839-44.
Granfors T, Modig H, Damber J-E, Tomic R. Combined orchiectomy and external radiotherapy versus radiotherapy alone for nonmetastatic prostate cancer with or without pelvic lymph node involvement: A prospective randomized study. J Urol. 1998 Jun;159(6):2030-4.
Hasselblad V. Numerical techniques in distribution fitting. Comp Sci Stat. 1994;26:217-21.
Hasselblad V. Meta-analysis of multitreatment studies. Med Decision Making. 1998 Jan;18(1):37-43.
Hedges LV, Olkin I, editors. Statistical methods for meta-analysis. Orlando: Academic Press; 1985.
Herbst WP. Effects of estradiol dipropionate and diethyl stilbestrol on malignant prostatic tissue. Trans Am Assoc Genitourin Surg. 1941;34:195-202.
Herbst WP. Biochemical therapeusis in carcinoma of the prostate gland: Preliminary report. JAMA. 1942;120:1116-20.
Herr H, Kornblith AB, Ofman U. A comparison of the quality of life of patients with metastatic prostate cancer who received or did not receive hormonal therapy. Cancer. 1993 Feb 1;71(3 Suppl):1143-50.
Hillner BE, McLeod DG, Crawford ED, Bennett CL. Estimating the cost effectiveness of total androgen bockade with flutamide in M1 prostate cancer. Urology. 1995 Apr;45(4):633-40.
Hoechst Marion Roussel, Inc. Nilandron® (nilutamide) tablet prescribing information. Kansas City, MO; 1996 Sep.
Holtgrewe HL, Bay-Nielsen H, Bouffioux C, et al. The economics of prostate cancer. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997. p. 399-414.
Huben RP, Murphy GP. A comparison of diethylstilbestrol or orchiectomy with buserelin and with methotrexate plus diethylstilbestrol or orchiectomy in newly diagnosed patients with clinical stage D2 cancer of the prostate. Cancer. 1988 Nov 1;62(9):1881-7.
Huben RP, Perrapato SD. Drug therapy of prostatic cancer. Drugs Aging. 1991 Sep;1(5):353-63.
Huggins C, Hodges CV. Studies on prostate cancer. 1. The effects of castration, of estrogen and of androgen injection on serum phosphatases in metastatic carcinoma of the prostate. Cancer Res. 1941;1:293-7.
Huggins C, Scott WW. Bilateral adrenalectomy in prostate cancer. Ann Surg. 1945;122:1031-41.
Huggins C, Stevens RE, Hodges CV. Studies on prostatic cancer, II: The effects of castration on advanced carcinoma of the prostate gland. Arch Surg. 1941;43:209-23.
Hurst KS, Byar DP. An analysis of the effects of changes from the assigned treatment in a clinical trial of treatment for prostatic cancer. J Chronic Dis. 1973 May;26(5):311-24.
Hussain MH, Crawford ED. Androgen deprivation strategies for metastatic prostate cancer. In: Rhagavan D, Scher RI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 591-7.
Iversen P. Zoladex plus flutamide vs. orchidectomy for advanced prostatic cancer. Danish Prostatic Cancer Group (DAPROCA). Eur Urol. 1990;18(Suppl 3):41-4. [pmid: 2151275].
Iversen P. Update of monotherapy trials with the new anti-androgen, Casodex (ICI 176,334). International Casodex Investigators. Eur Urol. 1994;26 (Suppl 1):5-9. [pmid: 7737258].
Iversen P. Combined androgen blockade in the treatment of advanced prostate cancer-an overview. The Scandinavian Prostatic Cancer Group. Scand J Urol Nephrol. 1997 Jun;31(3):249-54. [pmid: 9249887].
Iversen P, Tveter K, Varenhorst E. Randomised study of Casodex 50 MG monotherapy vs orchidectomy in the treatment of metastatic prostate cancer. The Scandinavian Casodex Cooperative Group. Scand J Urol Nephrol. 1996 Apr;30(2):93-8.
Iversen P, Christensen MG, Friis E, Hornbol P, Hvidt V, Iversen HG, Klarskov P, Krarup T, Lund F, Mogensen P, et al. A phase III trial of zoladex and flutamide versus orchiectomy in the treatment of patients with advanced carcinoma of the prostate. Cancer. 1990 Sep 1;66(5 Suppl):1058-66.
Iversen P, Rasmussen F, Klarskov P, Christensen IJ. Long-term results of Danish Prostatic Cancer Group trial 86. Goserelin acetate plus flutamide versus orchiectomy in advanced prostate cancer. Cancer. 1993 Dec 15;72(12 Suppl):3851-4.
Iversen P, Tyrrell CJ, Kaisary AV, Anderson JB, Baert L, Tammela T, Chamberlain M, Carroll K, Gotting-Smith K, Blackledge GR. Casodex (bicalutamide) 150-mg monotherapy compared with castration in patients with previously untreated nonmetastatic prostate cancer: Results from two multicenter randomized trials at a median follow-up of 4 years. Urology. 1998 Mar;51(3):389-96.
Jacobsen SJ, Katusic SK, Bergstralh EJ, Oesterling JE, Ohrt D, Klee GG, Chute CG, Lieber MM. Incidence of prostate cancer diagnosis in the eras before and after serum prostate-specific antigen testing. JAMA. 1995 Nov 8;274(18):1445-9.
Janknegt RA. Total androgen blockade with the use of orchiectomy and nilutamide (Anandron) or placebo as treatment of metastatic prostate cancer. Anandron International Study Group. Cancer. 1993 Dec 15;72(12 Suppl):3874-7. [pmid: 8252507].
Janknegt RA, Abbou CC, Bartoletti R, Bernstein-Hahn L, Bracken B, Brisset JM, Da Silva FC, Chisholm G, Crawford ED, Debruyne FM, et al. Orchiectomy and nilutamide or placebo as treatment of metastatic prostatic cancer in a multinational double-blind randomized trial. J Urol. 1993 Jan;149(1):77-82.
Jewett HJ. The present status of radical prostatectomy for stages A and B prostatic cancer. Urol Clin North Am. 1975 Feb;2(1):105-24. [pmid: 1128746].
Johansson J-E, Holmberg L, Johansson S, Bergstrom R, Adami H-O. Fifteen-year survival in prostate cancer. A prospective, population-based study in Sweden. JAMA. 1997 Feb 12;277(6):467-71.
Jordan WP Jr, Blackard CE, Byar DP. Reconsideration of orchiectomy in the treatment of advanced prostatic carcinoma. South Med J. 1977 Dec;70(12):1411-3.
Jorgensen T, Tveter KJ, Jorgensen LH. Total androgen suppression: experience from the Scandinavian Prostatic Cancer Group Study No. 2. Eur Urol. 1993;24(4):466-70. [pmid: 8287887].
Jorgensen T, Muller C, Kaalhus O, Danielsen HE, Tveter KJ. Extent of disease based on initial bone scan: important prognostic predictor for patients with metastatic prostatic cancer. Experience from the Scandinavian Prostatic Cancer Group Study No. 2 (SPCG-2). Eur Urol. 1995;28(1):40-6. [pmid: 8521893].
Jurincic CD, Horlbeck R, Klippel KF. Combined treatment (goserelin plus flutamide) versus monotherapy (goserelin alone) in advanced prostate cancer: a randomized study. Semin Oncol. 1991 Oct;18(5 Suppl 6):21-5.
Jurincic Winkler C, Horlbeck R, Gasser A, Klippel KF. The treatment of advanced prostate carcinoma with goserelin acetate (Zoladex (r)) and goserelin acetate plus flutamide (Fugerel (r)). Dtsch Z Onkol. 1992;24(3):65-70.
Kaisary AV. Current clinical studies with a new nonsteroidal antiandrogen, Casodex. Prostate Suppl. 1994;5:27-33. [pmid: 8172713].
Kaisary AV, Ryan PG, Turkes A, Peeling WB, Griffiths K. A comparison between surgical orchidectomy and LH-RH analogue ('Zoladex', ICI 118,630) in the treatment of advanced prostatic carcinoma-a multi-centre clinical study. Prog Clin Biol Res. 1988;260:89-100. [pmid: 2966408].
Kaisary AV, Tyrrell CJ, Beacock C, Lunglmayr G, Debruyne F. A randomised comparison of monotherapy with Casodex 50 mg daily and castration in the treatment of metastatic prostate carcinoma. Casodex Study Group. Eur Urol. 1995;28(3):215-22. [pmid: 8536775].
Kaisary AV, Tyrrell CJ, Peeling WB, Griffiths K. Comparison of LHRH analogue (Zoladex) with orchiectomy in patients with metastatic prostatic carcinoma. Br J Urol. 1991 May;67(5):502-8.
Kaplan RM, Anderson JP. A general policy model: update and applications. Health Serv Res. 1988 Jun;23(2):203-35.
Kelly WK, Slovin S, Scher HI. Steroid hormone withdrawal syndromes. Pathophysiology and clinical significance. Urol Clin North Am. 1997 May;24(2):421-31.
Kennealey GT, Vogelzang NJ, Soloway MS, Schellhammer P, Sharifi R, Block N, Venner P, Patterson L, Sarosdy M, Jones J, et al. Analysis of time to treatment failure by extent of disease and race in a randomized, multicenter trial comparing Casodex (bicalutamide) (C) with Eulexin (flutamide) (E), each combined with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Keuppens F, Denis L, Smith P, Carvalho AP, Newling D, Bond A, Sylvester R, De Pauw M, Vermeylen K, Ongena P. Zoladex and flutamide versus bilateral orchiectomy. A randomized phase III EORTC 30853 study. The EORTC GU Group. Cancer. 1990 Sep 1;66(5 Suppl):1045-57.
Keuppens F, Whelan P, Carneiro de Moura JL, Newling D, Bono A, Denis L, Robinson M, Mahler C, Sylvester R, De Pauw M, et al. Orchidectomy versus goserelin plus flutamide in patients with metastatic prostate cancer (EORTC 30853). European Organization for Research and Treatment of Cancer-Genitourinary Group. Cancer. 1993 Dec 15;72(12 Suppl):3863-9.
Kienle E, Lubben G. Efficacy and safety of leuprorelin acetate depot for prostate cancer. The German Leuprorelin Study Group. Urol Int. 1996;56 Suppl:123-30.
Kirby R, Fitzpatrick J, Kirby M, et al. A shared care for prostate diseases. ISIS Medical Media; 1994.
Klijn JG, de Voogt HJ, Studer UE, Schroder FH, Sylvester R, De Pauw M. Short-term versus long-term addition of cyproterone acetate to buserelin therapy in comparison with orchidectomy in the treatment of metastatic prostate cancer. European Organization for Research and Treatment of Cancer-Genitourinary Group. Cancer. 1993 Dec 15;72(12 Suppl):3858-62.
Klioze SS, Miller MF, Spiro TP. A randomized, comparative study of buserelin with DES/orchiectomy in the treatment of stage D2 prostatic cancer patients. Am J Clin Oncol. 1988;11(Suppl 2):S176-S182. [pmid: 3149455].
Klosterhalfen H, Becker H. Results of a 10-year randomised prospective study in metastasised prostate cancer. Aktuel Urol. 1987;18(5):234-6.
Klotz LH, Sogani PC, Block NL. Summary of intermittent endocrine therapy for advanced prostate cancer (by Lawrence H. Klotz, MD, Harry W. Herr, MD, Michael J. Morse, MD, and Willet F. Whitmore, Jr., MD). 1986. Semin Urol Oncol. 1997 May;15(2):117-22.
Knonagel H, Bolle JF, Hering F, Senn E, Hodel T, Neuenschwander H, Biedermann C. [Therapy of metastatic prostatic cancer by orchiectomy plus Anandron versus orchiectomy plus placebo. Initial results of a randomized multicenter study]. Helv Chir Acta. 1989 Aug;56(3):343-5.
Kolvenbag G, Blackledge GR, Gotting-Smith K. Bicalutamide (Casodex) in the treatment of prostate cancer: history of clinical development. Prostate. 1998 Jan 1;34(1):61-72.
Koutsilieris M, Tolis G. Long-term follow-up of patients with advanced prostatic carcinoma treated with either buserelin (HOE 766) or orchiectomy: Classification of variables associated with disease outcome. Prostate. 1985;7(1):31-9. [pmid: 3936031].
Krahn MD, Mahoney JE, Eckman MH, Trachtenberg J, Pauker SG, Detsky AS. Screening for prostate cancer. A decision analytic view. JAMA. 1994 Sep 14;272(10):773-80.
Kuban DA, El-Mahdi AM, Schellhammer PF. Prognosis in patients with local recurrence after definitive irradiation for prostatic carcinoma. Cancer. 1989 Jun 15;63(12):2421-5.
Kuban DA, El-Mahdi AM, Schellhammer PF. Prostate-specific antigen for pretreatment prediction and posttreatment evaluation of outcome after definitive irradiation for prostate cancer. Int J Rad Oncol Biol Phys. 1995a;32(2):307-16.
Kuban DA, El-Mahdi AM, Schellhammer PF. Potential benefit of improved local tumor control in patients with prostate carcinoma. Cancer. 1995b May 1;75(9):2373-82.
Labrie F, Belanger A, Cusan L, Labrie C, Simard J, Luu-The V, Diamond P, et al. History of LHRH agonist and combination therapy in prostate cancer. Endocrine Rel Cancer. 1996;3:243-78.
Labrie F, Dupont A, Belanger A, Cusan L, Lacourciere Y, Monfette G, Laberge JG, Emond JP, Fazekas AT, Raynaud JP, et al. New hormonal therapy in prostatic carcinoma: Combined treatment with an LHRH agonist and an antiandrogen. Clin Invest Med. 1982;5(4):267-75. [pmid: 6819101].
Landis SH, Murray T, Bolden S, Wingo PA. Cancer Statistics, 1998. CA Cancer J Clin. 1998 Jan/Feb;48(1):6-29.
Lee WR, Hanks GE, Schultheiss TE. The role of radiation therapy in the management of of stage T3-T4 prostate cancer: rationale, technique, and results with standard radiation, conformal therapy, proton and neutron beam therapy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 790-8.
Lerner SE, Blute WR, Zincke H. Primary surgery for clinical stage T3 adenocarcinoma of the prostate. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 803-11.
Lillis P, Thompson IM. Should asymptomatic progression following definitive local treatment for prostate cancer be treated?. Hematol Oncol Clin North Am. 1996 Jun;10(3):703-12.
Litwin MS, Lubeck DP, Henning JM, Carroll PR. Differences in urologist and patient assessments of health related quality of life in men with prostate cancer: Results of the CaPSURE database. J Urol. 1998 Jun;159(6):1988-92.
Lucas MD, Strijdom SC, Berk MM, Hart GA. Quality of life, sexual functioning and sex role identity after surgical orchiectomy in patients with prostatic cancer. Scand J Urol Nephrol. 1995 Dec;29(4):497-500.
Lund F, Rasmussen F. Flutamide versus stilboestrol in the management of advanced prostatic cancer. A controlled prospective study. Br J Urol. 1988 Feb;61(2):140-2.
Lunglmayr G. 'Zoladex' versus 'Zoladex' plus flutamide in the treatment of advanced prostate cancer. First interim analysis of an international trial. International Prostate Cancer Study Group. Prog Clin Biol Res. 1989;303:145-51. [pmid: 2528737].
Lunglmayr G. Efficacy and tolerability of Casodex in patients with advanced prostate cancer. Anticancer Drugs. 1995;6(4):508-13. [pmid: 7579554].
Maatman TJ, Gupta MK, Montie JE. Effectiveness of castration versus intravenous estrogen therapy in producing rapid endocrine control of metastatic cancer of the prostate. J Urol. 1985 Apr;133(4):620-1.
MacFarlane JR, Tolley DA. Flutamide therapy for advanced prostatic cancer: A phase II study. Br J Urol. 1985;57(2):172-4. [pmid: 3986452].
Mahler C, Denis LJ. Hormone refractory disease. Semin Surg Oncol. 1995 Jan;11(1):77-83.
Mahler CH, Akaza H, Boccardo F, et al. Secondary hormonal treatment. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd; 1997 p. 305-24.
Mazeman E, Bertrand P. Early versus delayed hormonal therapy in advanced prostate cancer. Eur Urol. 1996;30(Suppl 1):40-3.
McEvoy GK, editor. Diethylstilbestrol, diethylstilbestrol diphosphate. In: AHFS Drug Information 1997. Bethesda: American Society of Health-system Pharmacists; 1997. p. 2399-401.
McLeod DG. Antiandrogenic drugs. Cancer. 1993 Feb 1;71(3 Suppl):1046-9. [pmid: 8428326].
McLeod DG, Crawford ED, DeAntoni EP. Combined androgen blockade: the gold standard for metastatic prostate cancer. Eur Urol. 1997;32 (Suppl 3):70-7. [pmid: 9267789].
McLeod DG, Crawford ED, Blumenstein BA, Eisenberger MA, Dorr FA. Controversies in the treatment of metastatic prostate cancer. Cancer. 1992 Jul 1;70(1 Suppl):324-8.
Medical Research Council Working Party Investigators Group. Immediate versus deferred treatment for advanced prostatic cancer: Initial results of the Medical Research Council Trial. Br J Urol. 1997 Feb;79(2):235-46.
Metz R, Namer M, Adenis L, Audhuy B, Bugat R, Colombel P, Couette JE, Grise P, Khater R, LePorz B, et al. Zoladex as primary therapy in advanced prostatic cancer. A French cooperative trial. Am J Clin Oncol. 1988;11(Suppl 2):S112-S114. [pmid: 2977263].
Middleton RG, Thompson IM, Austenfeld MS, Cooner WH, Correa RJ, Gibbons RP, Miller HC, Oesterling JE, Resnick MI, Smalley SR, et al. Prostate Cancer Clinical Guidelines Panel summary report on the management of clinically localized prostate cancer. J Urol. 1995 Dec;154(6):2144-8.
Miller DK, Homan SM. Determining transition probabilities: Confusion and suggestions. Med Decis Making. 1994 Jan;14(1):52-8.
Moffat LE. Comparison of Zoladex, diethylstilbestrol and cyproterone acetate treatment in advanced prostate cancer. Eur Urol. 1990;18(Suppl 3):26-7. [pmid: 2151272].
Moher D, Jadad A, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: An annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
Moinpour CM, Savage M, Lovato L, Troxel A, Skeel R, Eisenberger MA, Crawford ED, Meyskens FL Jr. Quality of life (QOL) endpoints in advanced stage prostate cancer: A randomized, double blind study comparing flutamide to placebo in orchiectomized stage D2 prostate patients (PTS) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1997;16.
Moinpour CM, Savage MJ, Troxel A, Lovato LC, Eisenberger M, Veith RW, Higgins B, Skeel R, Yee M, Blumenstein BA, et al. Quality of life in advanced prostate cancer: results of a randomized therapeutic trial. J Natl Cancer Inst. 1998;90(20):1537-44. [pmid: 9790546].
Mosteller F, Gilbert JP, McPeek B. Reporting standards and research strategies for controlled trials. Agenda for the editor. Controlled Clin Trials. 1980;1:37-58.
Moul JW. Contemporary hormonal management of advanced prostate cancer. Oncology (Huntingt). 1998 Apr;12(4):499-505. [pmcid: 419372]. [pmid: 9575524].
Mulrow CD, Oxman AD, editors. Cochrane Collaboration Handbook [updated 9 December 1996]. Available in The Cochrane Library [database on disk and CDROM]. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
Namer M, Amiel J, Toubol J. Anandron (RU 23908) associated with orchiectomy in stage D prostate cancer. Preliminary results of a randomized, double-blind study. Am J Clin Oncol. 1988;11 (Suppl 2):S191-6. [pmid: 3071952].
Namer M, Toubol J, Caty A, Couette JE, Douchez J, Kerbrat P, Droz JP. A randomized double-blind study evaluating Anandron associated with orchiectomy in stage D prostate cancer. J Steroid Biochem Mol Biol. 1990 Dec 20;37(6):909-15.
Navratil H. Double-blind study of Anandron versus placebo in stage D2 prostate cancer patients receiving buserelin. Results on 49 cases from a multicentre study. Prog Clin Biol Res. 1987;243A:401-10. [pmid: 3116551].
Newling DW. The palliative therapy of advanced prostate cancer, with particular reference to the results of recent European clinical trials. Br J Urol. 1997 Mar;79(Suppl 1):72-81. [pmid: 9088277].
Newling DW, Denis L, Vermeylen K. Orchiectomy versus goserelin and flutamide in the treatment of newly diagnosed metastatic prostate cancer. Analysis of the criteria of evaluation used in the European Organization for Research and Treatment of Cancer--Genitourinary Group Study 30853. Cancer. 1993 Dec 15;72(12 Suppl):3793-8.
Newling DW, Pavone Macaluse M, Smith P, de Voogt HJ, Robinson MR, Schroder FH, Denis L, Jones WG, de Pauw M, Sylvester R. Update of EORTC clinical trials in prostate cancer. The EORTC Genito-Urinary Group. Semin Urol. 1992 Feb;10(1):65-71.
Nicholson S, Waxman J. Prostate cancer and endocrine therapy. Endocr Rel Cancer. 1997;4(2):141-52.
Nord E. Methods for quality adjustment of life years. Soc Sci Med. 1992;34:560-6.
Oesterling J, Fuks Z, Lee CT, Scher HI. Cancer of the prostate. In: DeVita VT Jr., Hellman S, Rosenberg SA, editors. Cancer: Principles and practice of oncology. 5th ed. Philadelphia: Lippincott-Raven; 1997. p. 1322-86.
Oosterlinck W, Casselman J, Mattelaer J, Van Velthoven R, Kurjatkin O, Schulman C. Tolerability and safety of flutamide in monotherapy, with orchiectomy or with LHRH-a in advanced prostate cancer patients. A Belgian multicenter study of 905 patients. Eur Urol. 1996;30(4):458-63. [pmid: 8977067].
Ostri P, Bonnesen T, Nilsson T, Frimodt-Moller C. Treatment of symptomatic metastatic prostatic cancer with cyproterone acetate versus orchiectomy: A prospective randomized trial. Urol Int. 1991;46(2):167-71. [pmid: 1711250].
Parametric cost estimating reference manual: inflation calculator. NASA [cited Jan 16, 1998]. Available from: URL: http://www.jsc.nasa.gov/bu2/inflate.html.
Partin AW, Kattan MW, Subong ENP, Walsh PC, Wojno KJ, Oesterling JE, Scardino PT, Pearson JD. Combination of prostate-specific antigen, clinical stage, and Gleason score to predict pathological stage of localized prostate cancer: A multi-institutional update. JAMA. 1977 May;277(18):1445-51.
Patrick DL, Erickson P. Health status and health policy. Allocating resources to health care. New York: Oxford University Press; 1993.
Pavone-Macaluso M, de Voogt HJ, Viggiano G, Barasolo E, Lardennois B, de Pauw M, Sylvester R. Comparison of diethylstilbestrol, cyproterone acetate and medroxyprogesterone acetate in the treatment of advanced prostatic cancer: Final analysis of a randomized phase III trial of the European Organization for Research on Treatment of Cancer Urological Group. J Urol. 1986 Sep;136(3):624-31.
Pavone-Macaluso M, Ingargiola GB, de Voogt H, Viggiano G, Barasolo E, Lardennois B, De Pauw M, Sylvester R. Cyproterone acetate versus medroxyprogesterone acetate versus diethylstilbestrol in the treatment of prostate cancer: Results from EORTC Study 30761. Prog Clin Biol Res. 1987;243A:379-82. [pmid: 2958862].
Pavone-Macaluso M, Martinez-Pineiro JA, de Voogt H, Lardennois B, Nasta A, Zolfanelli R, Barasolo E, De Pauw M, Suciu S, Sulvester R. [Treatment of prostatic cancer: medroxyprogesterone acetate, diethylstilbestrol and cyproterone acetate. Provisional report of a random study by the genito-urinary cooperative group of the EORTC]. Arch Esp Urol. 1982 Sep-Oct;35(5):304-11.
Peeling WB. Randomised controlled trial of treatment of patients with prostatic cancer: Orchidectomy, diethylstilboestrol, cyproterone acetate. Monogr Ser Eur Organ Res Treat Cancer. 1984;13:171-2.
Peeling WB. A comparison between surgical orchidectomy and the LHRH agonist 'Zoladex' (ICI 188630) in the treatment of metastatic cancer of the prostate. Prog Clin Biol Res. 1989a;303:41-5. [pmid: 2528738].
Peeling WB. Phase III studies to compare goserelin (Zoladex) with orchiectomy and with diethylstilbestrol in treatment of prostatic carcinoma. Urology. 1989b May;33(5 Suppl):45-52. [pmid: 2523611].
Perez CA. Prostate. In: Perez CA, Brady LW, editors. Principles and practice of radiation oncology. 3rd ed. Philadelphia: Lippincott-Raven; 1997. p. 1583-1694.
Periti P, Rizzo M, Mazzei T, Mini E. Depot leuprorelin acetate alone or with nilutamide in the treatment of metastatic prostate carcinoma: interim report of a multicenter, double-blind, placebo-controlled study [abstract]. Can J Infect. 1995;6(Suppl C).
Physician Data Query (PDQ) Database. Treatment of prostate cancer. Physician Data Query (PDQ) Information for Health Professionals. National Cancer Institute (NCI) web site. Available at: http://cancernet.nci.nih.gov/clinpdq/soa/Prostate_cancer_Physician.html. Last updated: 1/98; accessed February 4, 1998.
Pilepich MV. Combined radiation therapy and endocrine therapy in locally advanced prostate cancer. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 798-802.
Pilepich MV, Caplan R, Byhardt RW, Lawton CA, Gallagher MJ, Mesic JB, Hanks GE, Coughlin CT, Porter A, Shipley WU, et al. Phase III trial of androgen suppression using goserelin in unfavorable-prognosis carcinoma of the prostate treated with definitive radiotherapy: Report of the Radiation Therapy Oncology Group Protocol 85-31. J Clin Oncol. 1997;15:1013-21. [pmid: 9060541].
Pilepich MV, Krall JM, al-Sarraf M, John MJ, Doggett RL, Sause WT, Lawton CA, Abrams RA, Rotman M, Rubin P, et al. Androgen deprivation with radiation therapy compared with radiation therapy alone for locally advanced prostatic carcinoma: A randomized comparative trial of the Radiation Therapy Oncology Group. Urology. 1995 Apr;45(4):616-23.
Pilepich MV, Winter K, Roach M, Russell AH, Sause W, Rubin P, Byhardt R, et al. Phase III Radiation Therapy Oncology Group (RTOG) trial 86-10 of androgen deprivation before and during radiotherapy in locally advanced carcinoma of the prostate [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1998;17.
Plosker GL, Brogden RN. Leuprorelin. A review of its pharmacology and therapeutic use in prostatic cancer, endometriosis and other sex hormone-related disorders. Drugs. 1994 Dec;48(6):930-67.
Polednak AP. Estimating the prevalence of cancer in the United States. Cancer. 1997 Jul 1;80(1):136-41. [pmid: 9210719].
Presant CA, Soloway MS, Klioze SS, Yakabow A, Presant SN, Mendez RG, Kennedy PS, Wyres MR, Naessig VL, Todd B, et al. Buserelin treatment of advanced prostatic carcinoma. Long-term follow-up of antitumor responses and improved quality of life. Cancer. 1987 May 15;59(10):1713-6.
Prestidge BR, Prete JJ, Buchholz TA, Friedland JL, Stock RG, Grimm PD, Bice WS. A survey of current clinical practice of permanent prostate brachytherapy in the United States. Int J Radiat Oncol Biol Phys. 1998 Jan 15;40(2):461-5.
Prostate Cancer Trialists' Collaborative Group. Maximum androgen blockade in advanced prostate cancer: An overview of 22 randomised trials with 3283 deaths in 5710 patients. Lancet. 1995 Jul 29;346(8970):265-9.
Radiation Therapy Oncology Group. Phase III trial of androgen suppression before and during radiation therapy for locally advanced prostatic cancer: Abstract report of RTOG 8610. Prostate Suppl. 1994;5:2-3. [pmid: 8172711].
Reiter RE, Scardino PT, Miles BJ. Salvage radical prostatectomy for local recurrence of prostate cancer after radiation therapy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 817-28.
Ritter MA, Messing EM, Shanahan TG, Potts S, Chappell RJ, Kinsella TJ. Prostate-specific antigen as a predictor of radiotherapy response and patterns of failure in localized prostate cancer. J Clin Oncol. 1992 Aug;10(8):1208-17.
Robertson CN, Roberson KM, Padilla GM, O'Brien ET, Cook JM, Kim CS, Fine RL. Induction of apoptosis by diethylstilbestrol in hormone-insensitive prostate cancer cells. J Natl Cancer Inst. 1996 Jul 3;88(13):908-17.
Robinson MR. Complete androgen blockade: The EORTC experience comparing orchidectomy versus orchidectomy plus cyproterone acetate versus low-dose stilboestrol in the treatment of metastatic carcinoma of the prostate. Prog Clin Biol Res. 1987;243A:383-90. [pmid: 2958863].
Robinson MR. EORTC protocol 30805: A phase III trial comparing orchidectomy versus orchidectomy and cyproterone acetate and low dose stilboestrol in the management of metastatic carcinoma of the prostate. Prog Clin Biol Res. 1988;260:101-10. [pmid: 2966402].
Robinson MR. A further analysis of European Organization for Research and Treatment of Cancer protocol 30805. Orchidectomy versus orchidectomy plus cyproterone acetate versus low-dose diethylstilbestrol. Cancer. 1993 Dec 15;72(12 Suppl):3855-7.
Robinson MR, Smith PH, Macaluso MP, Sylvester R, de Voogt H. The EORTC Phase III trials in prostatic cancer. Prog Clin Biol Res. 1985;185A:243-9. [pmid: 3898132].
Robinson MR, Smith PH, Richards B, Newling DW, de Pauw M, Sylvester R. The final analysis of the EORTC Genito-Urinary Tract Cancer Co-Operative Group phase III clinical trial (protocol 30805) comparing orchidectomy, orchidectomy plus cyproterone acetate and low dose stilboestrol in the management of metastatic carcinoma of the prostate. Eur Urol. 1995;28(4):273-83. [pmid: 8575493].
Robson M, Dawson N. How is androgen-dependent metastatic prostate cancer best treated?. Hematol Oncol Clin North Am. 1996 Jun;10(3):727-47.
Roila F. Buserelin in the treatment of prostatic cancer. Biomed Pharmacother. 1989;43(4):279-85. [pmid: 2506941].
Rubben H, Dijkman G, Ferrari P, et al. Treatment of hormone resistant disease. In: Murphy G, Griffiths K, Denis L, et al., editors. First international consultation on prostate cancer. London: Scientific Communication International, Ltd.; 1997. p. 325-42.
Ryan PG, Peeling WB. U.K. trials of treatment for M1 prostatic cancer. The LH-RH analogue Zoladex vs. orchidectomy. Am J Clin Oncol. 1988;11(Suppl 2):S169-S172. [pmid: 2977272].
Sarosdy MF, Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Vogelzang NJ, Chodak GW, Klein EA, et al. Comparison of four combined androgen blockade (CAB regimens for stage D2 prostate cancer) [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1998a;17.
Sarosdy MF, Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Vogelzang NJ, Chodak GW, Klein EA, et al. Comparison of goserelin and leuprolide in combined androgen blockade therapy. Urology. 1998b Jul;52(1):82-8. [pmcid: 111060].
Schellhammer PF. Combined androgen blockade for the treatment of metastatic cancer of the prostate. Urology. 1996 May;47(5):622-8. [pmid: 8650856].
Schellhammer P, Sharifi R, Block N, Soloway M, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer. Casodex Combination Study Group. Urology. 1995 May;45(5):745-52.
Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Vogelzang NJ, Chen Y, Kolvenbag GJ. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate carcinoma. Analysis of time to progression. CASODEX Combination Study Group. Cancer. 1996a Nov 15;78(10):2164-9.
Schellhammer P, Sharifi R, Block N, Soloway M, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. Maximal androgen blockade for patients with metastatic prostate cancer: Outcome of a controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy. Casodex Combination Study Group. Urology. 1996b Jan;47(1A Suppl):54-60.
Schellhammer PF, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Vogelzang NJ, Schellenger JJ, Kolvenbag GJ. Clinical benefits of bicalutamide compared with flutamide in combined androgen blockade for patients with advanced prostatic carcinoma: Final report of a double-blind, randomized, multicenter trial. Casodex Combination Study Group. Urology. 1997 Sep;50(3):330-6. [pmcid: 115867].
Schellhammer PF, Vogelzang NJ, Sharifi R, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Jones JA, Kennealey GT, et al. Updated results of a randomized, double-blind trial in 813 previously untreated metastatic prostate cancer (CAP) patients (PTS) comparing the antiandrogens Casodex (bicalutamide) and Eulexin (flutamide) in combination with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1996;15.
Schering Corporation. Eulexin® (flutamide) capsules prescribing information. 1996 June. Kenilworth, NJ.
Schroder FH. Early versus delayed endocrine treatment in metastatic prostatic cancer. Prog Clin Biol Res. 1989;303:253-60. [pmid: 2674988].
Schroder FH. Cyproterone acetate-mechanism of action and clinical effectiveness in prostate cancer treatment. Cancer. 1993 Dec 15;72(12 Suppl):3810-5. [pmid: 8252496].
Schroder FH. Is there a best endocrine treatment of prostate cancer?. J Clin Endocrinol Metab. 1995 Apr;80(4):1071-4. [pmid: 7714069].
Schulman CC. Neoadjuvant androgen blockade prior to prostatectomy: A retrospective study and critical review. Prostate Suppl. 1994;5:9-14. [pmid: 7513532].
Schulze H, Kaldenhoff H, Senge T. Evaluation of total versus partial androgen blockade in the treatment of advanced prostatic cancer. Urol Int. 1988;43(4):193-7. [pmid: 2973169].
Seely JH. Phase III studies in prostatic cancer with leuprolide acetate. J Androl. 1987 Jan-Feb;8(1):S23-S26. [pmid: 3104263].
Small EJ, Vogelzang NJ. Second-line hormonal therapy for advanced prostate cancer: A shifting paradigm. J Clin Oncol. 1997 Jan;15(1):382-8.
Smith DC, Pienta KJ. The use of prostate-specific antigen as a surrogate end point in the treatment of patients with hormone refractory prostate cancer. Urol Clin North Am. 1997 May;24(2):433-7.
Smith PH, Pavone-Macaluso M, Viggiano G, de Voogt HD, Lardennois B, Robinson MR, Richards B, Glashan RW, de Pauw M, Sylvester R. EORTC protocols in prostatic cancer. Monogr Ser Eur Organ Res Treat Cancer. 1984;13:107-17.
Soloway MS, Matzkin H. Antiandrogenic agents as monotherapy in advanced prostatic carcinoma. Cancer. 1993 Feb 1;71(3 Suppl):1083-8.
Soloway MS, Chodak G, Vogelzang NJ, Block NL, Schellhammer PF, Smith JA Jr, Scott M, Kennealey G, Gau TC. Zoladex versus orchiectomy in treatment of advanced prostate cancer: A randomized trial. Zoladex Prostate Study Group. Urology. 1991 Jan;37(1):46-51.
Soloway MS, Schellhammer P, Sharifi R, Venner P, Patterson AL, Sarosdy M, Vogelzang N, Jones J, Kolvenbag G. A controlled trial of Casodex (bicalutamide) vs. flutamide, each in combination with luteinising hormone-releasing hormone analogue therapy in patients with advanced prostate cancer. Casodex Combination Study Group. Eur Urol. 1996;29(Suppl 2):105-9. [pmid: 8717471].
Sonnenberg FA, Beck JR. Markov models in medical decision making: A practical guide. Med Decis Making. 1993 Oct;13(4):322-8.
Stamey TA, Kabalin JN. Prostate specific antigen in the diagnosis and treatment of adenocarcinoma of the prostate: I. Untreated patients. J Urol. 1989 May;141(5):1070-5.
Stanford JL, Stephenson RA, Coyle LM, Cerhan J, Correa R, Eley JW, Gilliland F, Hankey B, Kolonel LN, Kosary C, et al. Prostate Cancer Trends: 1973-1995, SEER Program, National Cancer Institute. Bethesda, MD; 1998.
Swanson LJ, Garnick MB. Leuprolide versus diethylstilbestrol for metastatic prostatic cancer. Monogr Ser Eur Organ Res Treat Cancer. 1987;18:301-8.
Tannock IF, Osoba D, Stockler MR, Ernst DS, Neville AJ, Moore MJ, Armitage GR, Wilson JJ, Venner PM, Coppin CM, et al. Chemotherapy with mitoxantrone plus prednisone or prednisone alone for symptomatic hormone-resistant prostate cancer: A Canadian randomized trial with palliative end points. J Clin Oncol. 1996 Jun;14(6):1756-64.
TAP Pharmaceuticals, Inc. Lupron® (leuprolide acetate) injection prescribing information. Deerfield, IL; 1996 Apr.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 7.5 mg prescribing information. Deerfield, IL; 1997a Jun.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3 month (22.5 mg) prescribing information. Deerfield, IL; 1997b Mar.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 4 month (30 mg) prescribing information. Deerfield, IL; 1997c Jun.
TAP Pharmaceuticals, Inc. Lupron Depot-PED® (leuprolide acetate for depot suspension) prescribing information. Deerfield, IL; 1997d Mar.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3.75 mg prescribing information. Deerfield, IL; 1997e Apr.
TAP Pharmaceuticals, Inc. Lupron Depot® (leuprolide acetate for depot suspension) 3 month (11.25 mg) prescribing information. Deerfield, IL; 1997f Jul.
Taplin SH, Barlow W, Urban N, Mandelson MT, Timlin DJ, Ichikawa L, Nefcy P. Stage, age, comorbidity, and direct costs of colon, prostate, and breast cancer care. J Natl Cancer Inst. 1995 Mar 15;87(6):417-26.
The Canadian Anandron Study Group. Total androgen ablation in the treatment of metastatic prostatic cancer. Semin Urol. 1990 Aug;8(3):159-65.
The Leuprolide Study Group. Leuprolide versus diethylstilbestrol for metastatic prostate cancer. N Engl J Med. 1984 Nov 15;311(20):1281-6.
Thorpe SC, Azmatullah S, Fellows GJ, Gingell JC, O'Boyle PJ. A prospective, randomised study to compare goserelin acetate (Zoladex) versus cyproterone acetate (Cyprostat) versus a combination of the two in the treatment of metastatic prostatic carcinoma. Eur Urol. 1996;29(1):47-54. [pmid: 8821690].
Thrasher JB, Crawford ED. Combined androgen blockade. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams & Wilkins; 1996. p. 875-84.
Turkes AO, Griffiths K. Endocrine treatment of prostate cancer. Prog Med Chem. 1989;26:299-321. [pmid: 2532376].
Turkes AO, Peeling WB, Griffiths K. Treatment of patients with advanced cancer of the prostate: phase III trial, Zoladex against castration; a study of the British Prostate Group. J Steroid Biochem. 1987;27(1-3):543-9. [pmid: 2961938].
Tyrrell CJ, Altwein JE, Klippel F, Varenhorst E, Lunglmayr G, Boccardo F, Holdaway IM, Haefliger JM, Jordaan JP. A multicenter randomized trial comparing the luteinizing hormone-releasing hormone analogue goserelin acetate alone and with flutamide in the treatment of advanced prostate cancer. The International Prostate Cancer Study Group. J Urol. 1991 Nov;146(5):1321-6.
Tyrrell CJ, Altwein JE, Klippel F, Varenhorst E, Lunglmayr G, Boccardo F, Holdaway IM, Haefliger JM, Jordaan JP, Sotarauta M. Multicenter randomized trial comparing Zoladex with Zoladex plus flutamide in the treatment of advanced prostate cancer. Survival update. International Prostate Cancer Study Group. Cancer. 1993 Dec 15;72(12 Suppl):3878-9.
Van Poppel H, Ameye F, Oyen R, Van De Voorde W, Baert L. Neo-adjuvant hormonotherapy does not facilitate radical prostatectomy. Acta Urol Belg. 1992;60(3):73-82.
Veterans Administration Cooperative Urological Research Group. Treatment and survival of patients with cancer of the prostate. Surg Gynecol Obstet. 1967 May;124(5):1011-7.
Vogelzang NJ, Chodak GW, Soloway MS, Block NL, Schellhammer PF, Smith JA Jr, Caplan RJ, Kennealey GT. Goserelin versus orchiectomy in the treatment of advanced prostate cancer: final results of a randomized trial. Zoladex Prostate Study Group. Urology. 1995 Aug;46(2):220-6. [pmcid: 434513].
Vogelzang NJ, Kennealey GT. Recent developments in endocrine treatment of prostate cancer. Cancer. 1992 Aug 15;70(4 Suppl):966-76.
Vogelzang NJ, Schellhammer PF, Block NL, Soloway MS, Venner PM, Patterson AL, Sarosdy MF, Jones JA, Kennealey GT. A randomized double-blind trial in 813 previously untreated metastatic prostate cancer (CAP) patients (PTS) comparing a new antiandrogen Casodex (bicalutamide) with Eulexin (flutamide) in combination with luteinizing hormone releasing hormone analog (LHRH-a) therapy [abstract]. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Voges GE, Mottrie AM, Stockle M, Muller SC. Hormone therapy prior to radical prostatectomy in patients with clinical stage C prostate cancer. Prostate Suppl. 1994;5:4-8. [pmid: 7513531].
Walsh PC. Immediate versus deferred treatment for advanced prostate cancer: initial results of the medical research council trial. J Urol. 1997 Oct;158(4):1623-4. [pmid: 9302187].
Wang Y, Fair WR. Neoadjuvant hormonal therapy in prostate cancer. In: Raghavan D, Scher HI, Leibel SA, et al., editors. Principles and practice of genitourinary oncology. Philadelphia: Lippincott-Raven; 1997. p. 561-5.
Waymont B, Lynch TH, Dunn JA, Emtage LA, Arkell DG, Wallace DM, Blackledge GR. Phase III randomised study of Zoladex versus stilboestrol in the treatment of advanced prostate cancer. Br J Urol. 1992 Jun;69(6):614-20.
Whitehead A, Whitehead J. A general parametric approach to the meta-analysis of randomized clinical trials. Stat Med. 1991;10:1665-77. [pmid: 1792461].
Williams G, Asopa R, Abel PD, Smith C. Pituitary adrenal and gonadal endocrine suppression for the primary treatment of prostate cancer. Br J Urol. 1990 May;65(5):504-8.
Wojciechowski NJ, Carter CA, Skoutakis VA, Bess DT, Falbe WJ, Mickle TR. Leuprolide: A gonadotropin-releasing hormone analog for the palliative treatment of prostatic cancer. Drug Intell Clin Pharm. 1986;20:746-51. [pmid: 2429815].
Woolf SH. Screening for prostate cancer with prostate-specific antigen. An examination of the evidence. Engl J Med. 1995 Nov 23;333(21):1401-5.
Wysowski DK, Fourcroy JL. Flutamide hepatotoxicity. J Urol. 1996 Jan;155(1):209-12.
Zagars GK, Johnson DE, von Eschenback AC, Hussey DH. Adjuvant estrogen following radiation therapy for stage C adenocarcinoma of the prostate: Long-term results of a prospective randomized study. Int J Radiat Oncol Biol Phys. 1988 Jun;14(6):1085-91.
Zalcberg JR, Raghaven D, Marshall V, Thompson PJ. Bilateral orchidectomy and flutamide versus orchidectomy alone in newly diagnosed patients with metastatic carcinoma of the prostate-an Australian multicentre trial. Br J Urol. 1996 Jun;77(6):865-9.
Zeneca Pharmaceuticals. Zoladex® 3.6 mg (goserelin acetate) implant prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1996a Apr. p. 3194-6.
Zeneca Pharmaceuticals. Zoladex® 3-month (goserelin acetate) implant 10.8 mg prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1996b Apr. p. 3196-8.
Zeneca Pharmaceuticals. Casodex® (bicalutamide) tablets prescribing information. In: Physicians' desk reference. 23rd ed. Montvale, NJ: Medical Economics Company, 1997 Jan. p. 3151-3.
Zerbib M, Payan C. A controlled trial of bicalutamide versus flutamide, each in combination with luteinizing hormone-releasing hormone analogue therapy, in patients with advanced prostate cancer [letter; comment]. Urology. 1996 Oct;48(4):661-3. [pmcid: 140032].
Zietman AL. The role of radiation as adjuvant or salvage therapy following radical prostatectomy. In: Vogelzang NJ, Scardino PT, Shipley WU, et al., editors. Comprehensive textbook of genitourinary oncology. Baltimore: Williams and Wilkins; 1996. p. 782-90.
Zietman AL, Dallow KC, McManus PA, Heney NM, Shipley WU. Time to second prostate-specific antigen failure is a surrogate endpoint for prostate cancer death in a prospective trial of therapy for localized disease. Urology. 1996 Feb;47(2):236-9.
Zietman AL, Prince EA, Nakfoor BM, Shipley WU. Neoadjuvant androgen suppression with radiation in the management of locally advanced adenocarcinoma of the prostate: experimental and clinical results. Urology. 1997 Mar;49(Suppl 3A):74-83. [pmcid: 140032].