# Results and Conclusions III: Immediate Versus Deferred Androgen Suppression

## Key Questions

This chapter compares immediate to deferred androgen suppression as defined by the patient populations and questions below. These constitute distinct patient populations and treatment settings. They are considered separately because it is unknown whether findings from one population generalize to another population. All trials that met the study selection criteria for this chapter used monotherapy for androgen suppression. No trials compared early to deferred combined androgen blockade.

1 Patients: Men who have previously undergone definitive therapy (radical prostatectomy or radiation therapy) for initially localized prostate cancer. Question: Does initiation of androgen suppression immediately upon a rising prostate-specific antigen (PSA) improve outcomes compared to initiation of androgen suppression that is deferred until signs or symptoms of clinical progression?
2 Patients: Men who are newly diagnosed with locally advanced or asymptomatic metastatic prostate cancer and are undergoing primary therapy with androgen suppression. Question: Does primary androgen suppression initiated immediately at diagnosis improve outcomes compared to androgen suppression deferred until signs or symptoms of clinical progression?
3 Patients: Men who have locally advanced or asymptomatic metastatic prostate cancer and are undergoing radiation therapy. Question: Does adjuvant androgen suppression initiated with radiotherapy, and continued for several years or more, improve outcomes compared to radiotherapy alone followed by androgen suppression initiated at signs or symptoms of clinical progression?

## Hormonal Therapy at PSA Rise After Definitive Therapy

Trials are in progress to compare androgen suppression initiated at PSA rise to androgen suppression deferred until clinical signs or symptoms of progression among patients who have undergone definitive therapy (radical prostatectomy or radiation therapy) for initially localized prostate cancer. One such trial is EORTC protocol 30943 (Physician Data Query Database, 1998), which compares initiation of various monotherapies and combined androgen blockade regimens for a persistently elevated or rising PSA versus deferred initiation. No published results are available yet from these trials. Thus, this evidence report cannot provide any conclusions about the relative outcomes of immediate therapy at PSA rise versus therapy deferred until clinical signs of progression in patients who have undergone definitive therapy.

## Primary Hormonal Therapy for Newly Diagnosed Locally Advanced or Asymptomatic Metastatic Disease

Three trials including a total of 1,209 patients compared primary hormonal therapy initiated at diagnosis with primary hormonal therapy deferred until clinical progression of disease. These trials used comparable therapies (orchiectomy, DES 1 mg, or LHRH agonist) and definitions of immediate versus deferred therapy. The population for these trials consisted of patients with locally advanced (T3/T4) or metastatic (M1) disease, both symptomatic and asymptomatic. Two trials currently in progress, EORTC 30846 and EORTC 30891 ( Newling, Pavone Macaluse, Smith et al., 1992), also compare immediate versus deferred initiation of primary hormonal therapy.

### Interventions

The trial conducted by the Medical Research Council (MRC) Working Party Investigators Group randomized 938 patients (Medical Research Council Working Party Investigators Group, 1997). Immediate therapy was initiated within 6 weeks of study entry, using either orchiectomy or an LHRH agonist with a short-term course of antiandrogen to control tumor flare. Deferred therapy was initiated when clinically significant progression occurred, based on the treating physician's usual practice. Deferred therapy was initiated for symptoms of local progression almost as frequently as for metastatic symptoms.

One concern about the MRC trial involves whether patients in the deferred therapy arm were allowed to progress too far before initiation of hormonal therapy (Walsh, 1997). This concern is raised by evidence that 3 percent of patients experienced pathologic fracture or spinal cord compression before initiation of deferred therapy. If patients were allowed to progress too far, it creates the potential for bias that would inflate differences in outcomes between immediate and deferred therapy.

The Veterans Administration Cooperative Urological Research Group (VACURG) studies were placebo-controlled trials designed to examine the efficacy of orchiectomy, DES at various doses, and orchiectomy, alone or in combination with DES ( Blackard, Byar, and Jordan 1973 ; Byar and Corle, 1988 ; Christensen, Aagaard, and Madsen 1990 ; Hurst and Byar, 1973 ; Jordan, Blackard, and Byar, 1977 ; Veterans Administration Cooperative Urological Research Group, 1967 ). Hormonal therapies tested in the VACURG trials and found to be ineffective (e.g., DES 0.2 mg) or excessively toxic (e.g., DES 5 mg) are not reviewed here. In terms of comparing immediate to deferred androgen suppressive therapy, the first relevant comparison in the VACURG studies concerns the outcomes of patients who received immediate orchiectomy versus those of placebo-treated patients who received therapy at the first sign of disease progression; this comparison is referred to as "VACURG 1" in the tables (Blackard, Byar, and Jordan 1973; Veterans Administration Cooperative Urological Research Group, 1967). The second relevant VACURG comparison concerns outcomes of patients receiving immediate DES therapy (1 mg) versus those of placebo-treated patients who received therapy at the first sign of disease progression; this comparison is referred to as "VACURG 2" in the tables (Byar and Corle, 1988; Christensen, Aagaard, and Madsen 1990).

In the VACURG studies, placebo group patients received active therapy when the treating physician judged that a change of therapy was necessary for the welfare of the patient. Thus, patients in the placebo arm could be considered as having received deferred hormonal therapy. The most common reason for a change in therapy was that the patient was "too ill" to continue with the assigned treatment. In VACURG 1, after 9 years of followup, approximately 67 percent of stage III placebo group patients had received an active therapy, while 100 percent of stage IV placebo group patients changed treatment by this time. In the VACURG 2 trial, information is lacking about the degree to which stage III placebo patients underwent active treatment; however, 40 percent of stage IV patients who received placebo never underwent active hormonal therapy. Given that high proportion of untreated stage IV patients and uncertainty about subsequent treatment of stage III patients, the outcome comparisons of immediate and deferred groups in VACURG 2 must be viewed cautiously.

In each trial, patients in the deferred therapy arms were treated with a wider variety of interventions compared to patients in the immediate therapy arms. In the VACURG 1 trial (Blackard, Byar, and Jordan 1973; Veterans Administration Cooperative Urological Research Group, 1967), placebo patients who progressed mainly received DES or DES plus orchiectomy. The VACURG 2 study (Byar and Corle, 1988; Christensen, Aagaard, and Madsen 1990) did not report subsequent treatment of patients in the placebo arm. In the MRC study (Medical Research Council Working Party Investigators Group, 1997), 72 percent of the patients who had deferred therapy received orchiectomy and 24 percent received an LHRH agonist.

### Populations

The MRC and VACURG trials enrolled newly diagnosed, previously untreated patients with histologically confirmed locally advanced or metastatic disease. The MRC trial enrolled patients with "local disease considered too advanced for curative treatment (T2-T4)" or asymptomatic M1 disease (Medical Research Council Working Party Investigators Group, 1997). The VACURG trials, which used an earlier staging system, enrolled patients with stage III or IV disease. Stage III was defined as local extension beyond the prostatic capsule, whereas stage IV was marked by elevated prostatic acid phosphatase or demonstrated metastases.

The VACURG trials have not provided data regarding the comparability of patients in different treatment arms. The MRC paper noted that the randomization process used an algorithm to limit chance differences among groups in age, T stage, and M stage.

### Outcomes

Efficacy outcomes, which were measured at 5 years, included overall survival, cancer-specific survival, and time to progression. All three trials reported overall survival; two of the three reported cancer-specific survival; and 1 reported time to progression. In general, reporting of adverse events is sparse in these studies. The VACURG trials reported on cardiovascular deaths related to DES. No studies reporting on quality of life were identified.

An important limitation in most of these studies is incomplete followup of all patients. In the VACURG 1 study, only 44 percent of the patients in the placebo arm had progressed and had changed to an active treatment. There is no information from the VACURG 2 trial regarding the proportion of placebo patients who progressed or what treatments they underwent after progression. In the MRC trial, a more complete proportion of patients in the deferred arm (75 percent) had progressed and received hormonal therapy.

### Quality of Study Design and Conduct

All studies were randomized controlled trials. Overall study quality was assessed as described in the Methods section. Studies that were double-blinded and used an intent-to-treat analysis were classified as higher quality. Blinding was considered to be not applicable when the treatment was orchiectomy.

Evidence Table III.1 (in Appendix III) shows whether studies were blinded, whether intent-to-treat analyses were used, and whether withdrawals were documented. Of the three trials, two were assessed as being of higher quality, for purposes of performing sensitivity analyses. However, we judged the total number of studies too small to perform sensitivity analyses, and no sensitivity analysis is included in this meta-analysis.

## Hormonal Therapy as an Adjuvant to Radiation Therapy for Locally Advanced or Asymptomatic Metastatic Disease

Four trials, including a total of 1,529 patients, compared adjuvant androgen suppression initiated with radiotherapy, and continued for several years or more, to radiotherapy alone. The patients who initially underwent radiotherapy alone received hormonal therapy at the time of progression or relapse. The hormonal therapy used as the adjuvant in the immediate therapy arm was often used in the deferred treatment arm, although other agents were allowed. The population for these studies was mainly patients with locally advanced disease but also included patients with local disease (T1/T2) at high risk for progression in the two larger studies.

### Interventions

The two largest trials compared radiotherapy plus adjuvant goserelin to radiotherapy alone. The third trial used DES as the adjuvant hormonal therapy, and the fourth trial used orchiectomy.

The Radiation Therapy Oncology Group (RTOG) Protocol 85-31 (Pilepich, Caplan, Byhardt et al., 1997) randomized 977 patients to radiotherapy plus adjuvant goserelin (begun during the last week of radiation therapy and continued indefinitely or until progression) or to radiotherapy alone followed by observation and goserelin deferred until local failure, regional failure, or metastasis was observed. The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) randomized 415 patients to radiotherapy alone or radiotherapy plus adjuvant goserelin begun on the first day of radiotherapy and continued for 3 years. Zagars, Johnson, von Eschenback and coworkers (1988) randomized 82 patients to radiotherapy alone or radiotherapy plus 2 or 5 mg DES begun upon completion of radiation therapy and continued indefinitely or until withdrawal. Granfors, Modig, Damber and coworkers (1998) randomized 91 patients to radiation therapy alone or radiation therapy plus orchiectomy, performed 4 to 5 weeks before radiation therapy began.

### Populations

Within each of the four studies, patients in the two arms were well-balanced with respect to prognostic factors. Both the RTOG 85-31 trial ( Pilepich, Caplan, Byhardt et al., 1997) and the EORTC trial ( Bolla, Gonzalez, Warde et al., 1997) enrolled a mix of patients with locally advanced disease (T3/T4) and patients with localized disease who were at high risk for disease progression.

RTOG 85-31 (Pilepich, Caplan, Byhardt et al., 1997) enrolled patients with histologically confirmed T-3 disease or T1-T2 disease with regional lymph node involvement. Patients with bulky primary lesions were excluded (except those with extrapelvic nodal disease). The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) enrolled patients without prior treatment for prostate cancer who had histologically confirmed T3-T4,N0-X disease or T1-T2,N0 grade 3 disease. All patients in the Zagars, Johnson, von Eschenback and coworkers (1988) study had previously untreated stage C disease. Granfors, Modig, Damber and coworkers (1998) selected patients with T1-4, pathologically confirmed N0-3, M0 patients. Patients with negative lymph nodes were excluded if they had early stage disease or had well or moderately differentiated tumor.

Only the EORTC trial (Bolla, Gonzalez, Warde et al., 1997) included patients who had been previously treated. Some patients were included who had undergone radical prostatectomy if they had positive surgical margins or seminal vesicle involvement.

### Outcomes

Efficacy outcomes, which were measured at 5 years, included overall survival, cancer-specific survival, and time to progression/disease-free survival. The review of data on time to progression and disease-free survival include information on local control. All four trials reported overall survival; one of the four reported cancer-specific survival; all four trials reported disease-free survival; and two trials reported local control.

Adverse events related to hormonal therapy as an adjuvant to radiation therapy were reported in one trial. No studies reporting on quality of life were identified.

Lack of complete followup is shown in the two largest studies of hormonal therapy as an adjuvant to radiation therapy. The RTOG trial (Pilepich, Caplan, Byhardt et al., 1997) and the EORTC trial (Bolla, Gonzalez, Warde et al., 1997) indicated that 36 percent and 38 percent of patients in the radiation therapy alone arms had progressed and underwent hormonal therapy. The Zagars trial (Zagars, Johnson, von Eschenback et al., 1988) had more complete followup (68 percent of radiation alone patients had progressed), but this trial included only 80 patients. Granfors, Modig, Damber and coworkers (1998) had followup on progression for 61 percent of patients who underwent radiation therapy.

### Quality of Study Design and Conduct

All studies were randomized controlled trials. Overall study quality was assessed as described in the Methods section. Studies that were double-blinded and used an intent-to-treat analysis were classified as higher quality. Blinding was considered to be not applicable when the treatment was orchiectomy.

Evidence Table III.1 (in Appendix III) shows whether studies were blinded, whether intent-to-treat analyses were used, and whether withdrawals were documented. Of the four trials, none was assessed as being of higher quality for purposes of performing sensitivity analyses. However, we judged the total number of studies too small to perform sensitivity analyses, and no sensitivity analyses are included in the meta-analysis.

## Primary Hormonal Therapy for Newly Diagnosed Locally Advanced or Asymptomatic Metastatic Disease

### Overall Survival

Two of the three trials found a statistically significant difference in survival overall in favor of immediate therapy (Evidence Table III.2, Appendix III). The VACURG 2 study reported 5-year overall survival of 42 percent for patients who initially received DES 1 mg, compared to 30 percent for patients who were initially assigned to placebo (30 percent). The MRC trial reported that overall survival at 5 years in the immediate therapy group was 41 percent, compared with 37 percent in the deferred therapy group (p=0.02).

A subgroup analysis of the MRC trials found that the advantage for immediate therapy was observed only in M0 patients, who represented 53.5 percent of all patients. No difference between immediate and deferred therapy was found for patients with M1 disease (18.5 percent of patients) or MX disease (28 percent of patients).

The third trial, VACURG 1, found no statistically significant differences between placebo (deferred therapy) and immediate treatment with orchiectomy.

### Cancer-Specific Survival

Of two studies that reported cancer-specific survival, one found a statistically significant difference favoring immediate hormonal therapy (Evidence Table III.3, Appendix III). The MRC trial reported 59 percent cancer-specific survival at 5 years in the immediate therapy group and 46 percent in the deferred therapy group (p<0.001). VACURG 1 showed no difference between immediate orchiectomy and placebo.

### Time to Progression

Outcomes related to disease progression were reported only for the MRC trial, which found a statistically significant difference in favor of immediate therapy (Evidence Table III.4, Appendix III). Among patients without metastatic disease (about 54 percent of all patients), the time to distant progression was longer in the immediate group. At 5 years, 63 percent of immediate therapy patients were free of distant metastases, compared to 43 percent of deferred therapy patients (p<0.001).

Local progression was also slower in the immediate group, as measured by the number of patients requiring transurethral resection (TURP). Other indicators of progression showed an advantage for immediate therapy, including the frequency of spinal cord compression, ureteral obstruction, and development of extraskeletal metastases.

### Adverse Events

Reporting of adverse events data is sparse in these studies. The VACURG studies provide data only on cardiovascular deaths, which were similar in the immediate and deferred treatment arms. The MRC trial did not report data on adverse events related to hormonal therapy.

In general, adverse events would be expected to be those characteristic of the monotherapies. However, patients who undergo immediate treatment will have a longer duration of treatment, during which they experience these adverse events. In the MRC trial, duration of hormonal suppression was 18 months longer for the immediate treatment arm than for the deferred treatment arm.

## Hormonal Therapy as an Adjuvant to Radiation Therapy for Locally Advanced or Asymptomatic Metastatic Disease

### Overall Survival

Two trials and subgroup analysis of a third trial found a significant improvement in overall survival at 5 years for patients who received immediate adjuvant hormonal therapy (Evidence Table III.2, Appendix III). The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) reported 79 percent survival at 5 years for the group receiving immediate adjuvant hormonal therapy, compared to 62 percent for the deferred therapy group (p=0.001). Granfors, Modig, Damber and coworkers (1998) reported 83 percent survival at 5 years for immediate hormonal therapy, compared with 69 percent for deferred hormonal therapy (p=0.02).

In addition, a subgroup analysis from the RTOG trial on patients with Gleason scores of 8 to 10 found improved survival for the immediate adjuvant therapy group (66 percent at 5 years) over deferred hormonal therapy (55 percent, p=0.03). Granfors, Modig, Damber and coworkers (1998) also performed a subgroup analysis, which showed that the difference was significant in patients with node positive disease, but not in patients with node negative disease.

The RTOG 85-31 trial (Pilepich, Caplan, Byhardt et al., 1997), considering all patients, found no difference between the immediate therapy arm (75 percent at 5 years) versus the received deferred therapy arm (71 percent). The Zagars trial (Zagars, Johnson, von Eschenback et al., 1988) also found no differences between the immediate and deferred therapy arms.

### Cancer-Specific Survival

Only the Granfors trial (Granfors, Modig, Damber et al., 1998) reported on cancer-specific survival (Evidence Table III.3, Appendix III). The difference between groups in cancer-specific survival approached statistical significance (p=0.056), favoring the group that received immediate hormonal therapy.

### Time to Progression/Disease-Free Survival

Granfors, Modig, Damber and coworkers (1998) reported that the immediate adjuvant hormonal therapy group had significantly better progression-free survival (86 percent at 5 years), compared to the deferred therapy group (73 percent, p=0.005) (Evidence Table III.4, Appendix III). Immediate adjuvant hormonal therapy improved disease-free survival in all three studies that reported that outcome. In the RTOG 85-31 study (Pilepich, Caplan, Byhardt et al., 1997), patients who underwent immediate adjuvant therapy had significantly better disease-free survival at 5 years (60 percent) than did patients who received deferred therapy (44 percent, p<0.0001). The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) reported a similar finding (85 percent versus 48 percent, p<0.001). The difference between groups in the Zagars study (Zagars, Johnson, von Eschenback et al., 1988) was significant only at p=0.05 (66 percent versus 51 percent), possibly due to the study's small sample size.

Related outcomes showed similar advantages for immediate adjuvant therapy, including better rates of local control (RTOG 85-31 and EORTC), a slower rate of progression to distant metastases (RTOG 85-31), and better rates of disease-free survival that accounted for PSA values (RTOG 85-31)

### Adverse Events

The RTOG 85-31 trial (Pilepich, Caplan, Byhardt et al., 1997), the Zagars study (Zagars, Johnson, von Eschenback et al., 1988) and the Granfors trial (Granfors, Modig, Damber et al., 1998) reported no data on adverse events related to use of hormonal therapy. The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) reported a significantly higher incidence of grade 1 to 3 incontinence among immediate adjuvant therapy patients (29 percent) than in deferred therapy patients (16 percent, p=0.002).

In general, adverse events related to hormonal therapy would be expected to be those characteristic of the monotherapies. These reports do not provide information about the duration of therapy for either immediate or deferred arms. However, patients who undergo immediate treatment will have a longer duration of treatment during which they experience these adverse events.

## Meta-Analysis

The meta-analyses performed on trials comparing different monotherapies and trials comparing monotherapy with combined androgen blockade presented special challenges because of heterogeneity across trials with respect to the interventions used in both control and treatment arms. In contrast, trials comparing immediate versus deferred therapy were relatively homogeneous with respect to the interventions compared. Therefore, we can use more standard methods to combine the hazard ratios for 5-year mortality. The studies were combined using an empirical Bayes formula (see Hedges and Olkin, 1985). This is a random effects model that reduces to a fixed effects model when the studies show a homogeneous effect.

The studies using hormonal therapy as the primary treatment are shown in Table 18. The results are summarized as a hazard ratio where a smaller hazard ratio (less than 1) means that the treatment (immediate therapy) is superior to delayed treatment. The results are also shown graphically in Figure 10.

Table 18. Combined Estimates of the Effect of Immediate Treatment Where Hormonal Therapy Is the Primary Treatment

Study | Hazard Ratio | 95% Confidence Interval
VACURG 1a III | 1.000 | 0.776, 1.288
VACURG 1a IV | 1.000 | 0.789, 1.268
VACURG 2 III+IV | 0.721 | 0.522, 0.994
MRC | 0.897 | 0.756, 1.063
Combined | 0.914 | 0.815, 1.026

Figure 10. Survival at 5 years, Immediate vs Deferred Primary Hormonal Therapy for Previously Untreated Patients

The results suggest a possible mortality advantage for immediate treatment in studies where hormonal treatment is the primary therapy, although the combined result does not attain statistical significance.

It should be noted that the results presented above demonstrate a statistically significant result for only one study, VACURG 2, while this report previously mentioned that two of the three studies reported a statistically significant effect for immediate therapy. This apparent discrepancy reflects differences in data analysis methods. This meta-analysis was performed on 5-year hazard rates, whereas the individual studies performed analyses on the entire survival results. The MRC trial reported a significant effect for immediate therapy, using all survival data, whereas the 5-year hazard ratio and 95 percent confidence interval did not show a significant effect. The studies using radiotherapy plus adjuvant androgen suppression are shown in Table 19. The results are summarized as a hazard ratio. The results are also shown graphically in Figure 11.

Table 19. Combined Estimates of the Effect of Radiotherapy Plus Adjuvant Androgen Suppression Relative to Radiotherapy Alone

Study | Hazard Ratio | 95% Confidence Interval
RTOG | 0.840 | 0.656, 1.075
EORTC | 0.493 | 0.340, 0.715
Zagars | 0.757 | 0.336, 1.707
Granfors | 0.502 | 0.338, 0.746
COMBINED | 0.631 | 0.479, 0.831

Figure 11. Survival at 5 Years, Immediate vs Deferred Hormonal Therapy as Adjuvant to Radiation Therapy

The results suggest that there is a reduction in mortality associated with adjuvant androgen suppression initiated with radiotherapy and continued for several years or more, when compared with radiotherapy alone followed by androgen suppression at clinical progression.

## Summary and Conclusions

### Summary

This section compares the outcomes of immediate and deferred androgen suppression in three patient populations. These constitute distinct patient populations and treatment settings. They were considered separately because it is unknown whether findings from one population generalize to another population.

Trials are in progress to compare androgen suppression initiated at PSA rise to androgen suppression deferred until clinical signs or symptoms of progression among patients who have undergone definitive therapy (radical prostatectomy or radiation therapy) for initially localized prostate cancer. No published results are available yet from these trials.

Three trials including a total of 1,209 patients compared primary androgen suppression initiated at diagnosis with primary androgen suppression deferred until clinical progression of disease. The population for these trials consisted of patients with locally advanced (T3/T4) or metastatic (M1) disease, both symptomatic and asymptomatic.

Four trials, including a total of 1,529 patients, compared adjuvant androgen suppression, initiated with radiotherapy and continued for several years or more, to radiotherapy alone followed by androgen suppression at clinical progression. The population for these studies was mainly patients with locally advanced disease, but also included patients with local disease (T1/T2) at high risk for progression in the two larger studies.

### Conclusions

#### 1. The evidence is insufficient to determine whether hormonal therapy initiated immediately upon PSA rise after definitive therapy for initially localized disease improves outcomes compared to androgen suppression deferred until clinical signs or symptoms of progression

- Randomized controlled trials are in progress, but no results have yet been published.

#### 2. The evidence is insufficient to determine for patients with locally advanced or asymptomatic metastatic disease whether primary hormonal therapy initiated immediately at diagnosis improves outcomes compared to hormonal therapy deferred until clinical signs or symptoms of progression

- The body of evidence to address this question is limited to three trials (n=2,143), two of which were trials conducted in the 1960s (VACURG 1 and 2). None of the three trials had a uniform protocol for initiating deferred therapy, so deferred therapy in these trials reflects the varied practices of the treating physicians.
- Two (n=1,190) of the three trials reported a statistically significant difference in overall survival favoring the immediate therapy arm. The VACURG 2 trial reported 5-year overall survival of 42 percent in the immediate therapy arm compared to 30 percent in the deferred therapy arm. The Medical Research Council (MRC, 1997) trial reported that 5-year overall survival was 41 percent compared to 37 percent, but subgroup analysis found that the benefit was observed only in M0 patients.
- The meta-analysis found no significant difference between immediate primary hormonal therapy and deferred therapy at 5 years (hazard ratio 0.914; CI 0.815 to 1.026), although the 95 percent confidence interval approaches statistical significance.
- Patients who undergo immediate treatment will have a longer duration of treatment in which they experience the adverse effects of androgen suppression. In the MRC trial, the only trial that reported this data, duration of androgen suppression was 18 months longer in the immediate treatment arm.

#### 3. For patients with locally advanced or asymptomatic metastatic prostate cancer who undergo radiation therapy, the evidence suggests that adjuvant androgen suppression, initiated with radiotherapy and continued for several years or more, improves survival compared to radiotherapy alone followed by androgen suppression deferred until signs or symptoms of clinical progression

- Two trials (n=506) reported a statistically significant difference in 5-year overall survival favoring the adjuvant hormonal therapy arm. The EORTC trial (Bolla, Gonzalez, Warde et al., 1997) reported 5-year overall survival at 79 percent for the adjuvant hormonal therapy group compared to 62 percent for the deferred therapy group. Granfors, Modig, Damber and coworkers (1998) reported 5-year survival at 83 percent for adjuvant hormonal therapy compared with 69 percent for deferred hormonal therapy, but subgroup analysis found that the benefit was observed only in patients with node positive disease.
- Two trials (n=1,059) found no statistically significant difference in 5-year overall survival between the adjuvant hormonal therapy and deferred hormonal therapy arms. However, a subgroup analysis from the RTOG trial (Pilepich, Caplan, Byhardt et al., 1997) on patients with Gleason scores of 8 to 10 found improved 5-year overall survival for the adjuvant therapy group (66 percent versus 55 percent, p=0.03).
- The meta-analysis found a significant reduction in mortality associated with immediate hormonal therapy used as an adjuvant to radiation therapy compared with deferred hormonal therapy (hazard ratio 0.631; 95 percent CI 0.479 to 0.831).
- Patients who undergo adjuvant hormonal treatment will have a longer duration of hormonal therapy in which they experience the adverse effects of androgen suppression. However, these trials did not report data to compare the duration of hormonal therapy in the two arms.

#### 4. None of the trials that compared immediate and deferred androgen suppression reported data on quality of life