# Appendix IV: Data Abstraction Form

[Note: The data abstraction forms are not available online]