# Appendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

Appendix III. Abbreviation Key for Evidence Tables Appendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

% @ Endpt | | percentage of patients reaching endpoint
% ch | | percent change
% M1 | | percentage of patients with M1 disease
% PD | | percentage of patients with poorly differentiated tumor
% Sx | | percentage of patients with symptomatic disease
95% CI | | 95% confidence interval
ALT | | alanine aminotransferase
AST | | aspartate aminotransferase
bica | | bicalutamide
buser | | buserelin
CAB | | combined androgen blockade
CC | | comparison code
Comp Code | | comparison code
contin | | continuous
CV | | cardiovascular
Cx | | control group
cypr | | cyproterone
d | | day
d/c | | discontinued
DAPROCA | | Danish Prostate Cancer Group
DB? | | double-blind?
dec | | decreased
difs | | differences
Doc? | | withdrawals from enrollment documented?
EORTC | | European Organization for Research and Treatment of Cancer
f/u | | follow-up
fluta | | flutamide
GB | | Gehan-Breslow test
GI | | gastrointestinal
goser | | goserelin
grp | | group
GW | | Gehan-Wilcoxon test
GYN | | gynecomastia
HE | | hepatic
HF | | heart failure
HR | | hazard ratio
HT | | hormonal therapy
immed | | immediate
IN | | intranasal
ITT | | intention-to-treat analysis performed?
Leth | | lethal
leupr | | leuprolide
LHRH | | luteinizing hormone releasing hormone analog
LR | | log rank test
L-T | | life-threatening
MC | | Mantel-Cox test
Md | | median
Med | | median
MI | | myocardial infarction
Mn | | mean
mo | | month
Mod | | moderate
MRC | | Medical Research Council Prostate Cancer Working Party Investigators Group
N @R BL | | number of patients at risk at baseline
N Anlz | | number of patients analyzed
N C, T3-4 | | number of patients with stage C or T3-4 disease
N D1, N+ | | number of patients with stage D1 or node positive disease
N Enr | | number of patients enrolled
N Rand | | number of patients randomized
NCI SWOG/ECOG INT 0105 | | National Cancer Institute Southwest Oncology Group/Eastern Cooperative Oncology Group Intergroup Study 0101
nilut | | nilutamide
nonsignif | | nonsignificant
NPCP | | National Prostate Cancer Project
NSAA | | nonsteroidal antiandrogen
O/E | | observed to expected
Orch | | orchiectomy
os | | overall survival
PFS | | progression-free survival
pfs | | progression-free survival
plac | | placebo
PN | | pain
PONCAP | | Italian Prostate Cancer Project
pts | | patients
RE | | renal
RPMS | | Royal Postgraduate Medical School
RTOG | | Radiation Therapy Oncology Group
sc | | subcutaneous
Sev | | severe
SPCG | | Scandinavian Prostate Cancer Group
SR | | skin reaction
TIA | | transient ischemic attack
TTP | | time to disease progression
Tx | | treatment group
VACURG | | Veterans Administration Cooperative Urological Research Group
w/ | | with
WD | | withdrawal
wdl | | withdrawal
Westphalian PCSG | | Wesphalian Prostate Cancer Study Group
wk | | week
XRT | | external beam radiation therapy
yr | | year

Table III.1. Immediate vs. Deferred Hormonal Therapy, Patient Characteristics and MethodsAppendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

| | Intervention/Dose
Study | Stage | cx | tx | Blinding of Intervention | N C T3-4 cx | N D1 N+ cx | N C T3-4 cx | N D1 N+ tx | N Enr | N Rand cx | N Anlz cx | N Rand tx | N Anlz tx | WDs Documented | Intent to Treat? | Med Age cx | Med Age tx
VACURG 1 | III | placebo, delayed HT | orch + placebo | NA | | | | | 527 | 261 | 261 | 266 | 266 | yes | yes
VACURG 1 | IV | placebo, delayed HT | orch + placebo | NA | | | | | 426 | 223 | 223 | 203 | 203 | yes | yes
VACURG 2 | III+IV | placebo, delayed HT | DES, 1 mg qd | no | | | | | 256 | 128 | 128 | 128 | 128 | | yes
MRC immed | T2-4 | deferred orch/LHRHa | immend orch/LHRHa | NA | | | | | 938 | 465 | 465 | 469 | 469 | yes | yes
vs. Defferred | M1
RTOG 85-31 | T1/2,N+ | XRT, delayed HT | XRT+immed HT | no | 345 | 123 | 337 | 140 | 977 | 468 | 468 | 477 | 477 | yes | yes
| T3, NX
EORTC Trial | T1-4, | XRT, delayed HT | XRT+immed HT | no | 175 | 6 | 181 | 8 | 415 | 208 | 208 | 207 | 207 | yes | yes | 70 | 71
| N0-X,M0
Granfors 1998 | T1-4, | XRT, delayed HT | XRT+immed orch | no | 27 | 19 | 25 | 20 | 91 | 46 | 46 | 45 | 45 | yes | yes
| pN0-3,M0
Zagars 1988 | C | XRT, delayed HT | XRT+immed DES 2/5 | no | 39 | | 43 | | 82 | 43 | 40 | 39 | 38 | yes | no

Table III.2. Immediate vs. Deferred Hormonal Therapy, Overall SurvivalAppendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

| | Intervention/Dose
Study | Stage | cx | tx | N @R cx | N @R BL tx | Med (mo) cx | Med (mo) tx | 1 yr % cx | 1 yr % tx | 2 yr % cx | 2 yr % tx | 5 yr % cx | 5 yr % Tx | Stat Test | p value
VACURG 1 | III | placebo, delayed HT | orch + placebo | 261 | 266 | 65.0 | 67.0 | 87% | 89% | 75% | 77% | 53% | 53%
VACURG 1 | IV | placebo, delayed HT | orch + placebo | 223 | 203 | 27.0 | 30.0 | 73% | 78% | 53% | 57% | 25% | 25%
VACURG 2 | III+IV | placebo, delayed HT | DES, 1 mg qd | 128 | 128 | 34.0 | 43.0 | 82% | 84% | 65% | 68% | 30% | 42%
MRC Immed | T2-4 | deferred orch/LHRHa | immed orch/LHRHa | 465 | 469 | 46.0 | 49.0 | 91% | 91% | 77% | 78% | 37% | 41% | log rank O-E | 0.02
vs. Deferred | M1
RTOG 85-31 | T1/2,N+ | XRT, delayed HT | XRT+immed goser | 468 | 477 | | | 99% | 97% | 93% | 93% | 71% | 75% | log rank | 0.52
| T3, NX
EORTC Trial | T1-4, | XRT, delayed HT | XRT+immed goser | 208 | 207 | 75 | >108 | 97% | 98% | 92% | 94% | 62% | 79% | log rank | 0.001
| N0-X,M0
Granfors 1998 | T1-4, | XRT, delayed HT | XRT+immed orch | 46 | 45 | 100 | >131 | 98% | 100% | 89% | 98% | 69% | 83% | log rank | 0.02
| pN0-3,M0
Zagars 1988 | C | XRT, delayed HT | XRT+immed DES 2/5 | 38 | 40 | 104.0 | 114.0 | 96% | 93% | 89% | 84% | 66% | 73% | log rank | nonsig

Table III.3. Immediate vs. Deferred Hormonal Therapy, Cancer-Specific SurvivalAppendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

| | Intervention/Dose
Study | Stage | cx | tx | N @R cx | N @R BL tx | Med cx | Med tx | 1 yr % cx | 1 yr % tx | 2 yr % cx | 2 yr % tx | 5 yr % cx | 5 yr % tx | Stat Test | p value
VACURG 1 | III+IV | placebo, delayed HT | orch + placebo | 484 | 469 | | | 92% | 94% | 82% | 85% | 67% | 71%
VACURG 2 | III+IV | placebo, delayed HT | DES, 1 mg qd | 223 | 203
MRC Immed | T2-4 | deferred orch/LHRHa | immed orch/LHRHa | 465 | 469 | 56.0 | 78.0 | 96% | 96% | 82% | 84% | 46% | 59% | log rank O-E | 0.001
vs. Deferred | M1
RTOG 85-31 | T1/2,N+ | XRT, delayed HT | XRT+immed HT | 468 | 477
| T3, NX
EORTC Trial | T1-4 | XRT, delayed HT | XRT+immed HT | 208 | 207
Granfors 1998 | T1-4, | XRT, delayed HT | XRT+immed orch | 46 | 47 | 120.0 | >120.0 | 96% | 100% | 91% | 93% | 75% | 86% | log rank | 0.056
| pN0-3,M0
Zagars 1988 | C | XRT, delayed HT | XRT+immed DES 2/5 | 38 | 40

Table III.4. Immediate vs. Deferred Hormonal Therapy, Progression Outcomes/Disease-Free SurvivalAppendix III: Evidence Tables for Immediate Versus Deferred Androgen Suppression

| | Intervention/Dose
Study | Stage | cx | tx | N @R cx | N @R BL tx | Med cx | Med tx | 1 yr % cx | 1 yr % tx | 2 yr % cx | 2 yr % tx | 5 yr % cx | 5 yr % tx | Stat Test | p value | Comment
VACURG 1 | III+IV | placebo, delayed HT | orch + placebo | 484 | 469
VACURG 2 | III+IV | placebo, delayed HT | DES, 1 mg qd | 223 | 203
MRC Immed | T2-4 | deferred orch/LHRHa | immed orch/LHRHa | 244 | 256 | 49.0 | 96.0 | 84% | 96% | 70% | 89% | 43% | 63% | log rank O-E | <0.001 | M0 pts only
vs. Deferred | M1 | | | | | | 82.0
RTOG 85-31 | T1/2,N+ | XRT, delayed HT | XRT+immed HT | 468 | 477 | 53.0 | 74.0 | 87% | 93% | 73% | 83% | 44% | 60% | log rank | <0.0001
| T3, NX
EORTC Trial | T1-4 | XRT, delayed HT | XRT+immed HT | 208 | 207 | 60.0 | >108 | 87% | 99% | 73% | 95% | 48% | 85% | log rank | <0.001
Granfors 1998 | T1-4, | XRT, delayed HT | XRT+immed orch | 46 | 45 | 96.0 | >131 | 98% | 100% | 91% | 98% | 73% | 86% | log rank | 0.005
| pN0-3,M0
Zagars 1988 | C | XRT, delayed HT | XRT+immed DES 2/5 | 38 | 40 | | | 86% | 95% | 61% | 90% | 53% | 70% | log rank | ?