# Appendix II: Evidence Tables for Combined Androgen Blockade

The data summarized in Evidence Tables II-1 through II-8 are organized based on the specific comparisons made of monotherapies to combined androgen blockade, as listed below. The code number (left column) identifies each comparison. In each table, trials are identified by first author's name and year of the principal report. The list below also provides the number of trials and the number of literature citations for each comparison (right column).

Appendix II. Coding Key

code | comparison | available reports
1.1.0 | orchiectomy versus orchiectomy plus flutamide | 2 trials; 4 citations
1.2.0 | orchiectomy versus orchiectomy plus nilutamide | 5 trials; 16 citations
1.3.0 | orchiectomy versus orchiectomy plus bicalutamide | no trials
1.4.0 | orchiectomy versus orchiectomy plus cyproterone | 4 trials; 9 citations
2.1.1 | leuprolide versus leuprolide plus flutamide | 2 trials; 14 citations
2.1.2 | leuprolide versus leuprolide plus nilutamide | 2 trials; 2 citations
2.1.3 | leuprolide versus leuprolide plus bicalutamide | no trials
2.1.4 | leuprolide versus leuprolide plus cyproterone | no trials
2.2.1 | goserelin versus goserelin plus flutamide | 3 trials; 8 citations
2.2.2 | goserelin versus goserelin plus nilutamide | no trials
2.2.3 | goserelin versus goserelin plus bicalutamide | no trials
2.2.4 | goserelin versus goserelin plus cyproterone | 2 trials; 3 citations
2.3.1 | buserelin versus buserelin plus flutamide | 1 trial; 1 citation
2.3.2 | buserelin versus buserelin plus nilutamide | 1 trial; 1 citation
2.3.3 | buserelin versus buserelin plus bicalutamide | no trials
2.3.4 | buserelin versus buserelin plus cyproterone | 1 trial; 3 citations
2a.1 | (leuprolide or goserelin) plus flutamide vs. (leuprolide or goserelin) plus bicalutamide | 1 trial; 11 citations
3.1.1 | leuprolide or orchiectomy versus leuprolide or orchiectomy plus flutamide | no trials
3.1.2 | leuprolide or orchiectomy versus leuprolide or orchiectomy plus nilutamide | no trials
3.1.3 | leuprolide or orchiectomy versus leuprolide or orchiectomy + bicalutamide | no trials
3.1.4 | leuprolide or orchiectomy versus leuprolide or orchiectomy + cyproterone | no trials
3.2.1 | goserelin or orchiectomy versus goserelin or orchiectomy plus flutamide | 1 trial; 1 citation
| (no other trials of combined androgen blockade blended data for chemical and surgical castration)
4.1.1 | orchiectomy versus leuprolide plus flutamide | no trials
4.1.2 | orchiectomy versus goserelin plus flutamide | 2 trials; 14 citations
4.1.3 | orchiectomy versus buserelin plus flutamide | no trials
| (no trials compared orchiectomy with an LHRH agonist plus nilutamide or bicalutamide)
4.4.1 | orchiectomy versus leuprolide plus cyproterone | no trials
4.4.2 | orchiectomy versus goserelin plus cyproterone | no trials
4.4.3 | orchiectomy versus buserelin plus cyproterone | 1 trial; 4 citations

Alternatively, the body of literature can be organized by the antiandrogens used in the combination arms.

Combination | Monotherapy | Comparison Code | # Trials | N
Trials with flutamide:
orch + flutamide | orchiectomy | 1.1.0 | 2 | 1,593
leuprolide + flutamide | leuprolide | 2.1.1 | 2 | 844
goserelin + flutamide | goserelin | 2.2.1 | 3 | 1,187
buserelin + flutamide | buserelin | 2.3.1 | 1 | 122
leup/orch + flutamide | leup/orch | 3.1.1 | 0 | 0
goser/orch + flutamide | goser/orch | 3.2.1 | 1 | 99
leuprolide + flutamide | orchiectomy | 4.1.1 | 0 | 0
goserelin + flutamide | orchiectomy | 4.1.2 | 2 | 588
Trials with nilutamide:
orch + nilutamide | orchiectomy | 1.2.0 | 5 | 927
leuprolide + nilutamide | leuprolide | 2.1.2 | 2 | 537
goserelin + nilutamide | goserelin | 2.2.2 | 0 | 0
buserelin + nilutamide | buserelin | 2.3.2 | 1 | 38
leup/orch + nilutamide | leup/orch | 3.1.2 | 0 | 0
Trials with bicalutamide versus monotherapy | | 1.3.0; 2.X.3; | 0 | 0
Trials with cyproterone
orch + cyproterone | orchiectomy | 1.4.0 | 4 | 578
leuprolide + cyproterone | leuprolide | 2.1.4 | 0 | 0
goserelin + cyproterone | goserelin | 2.2.4 | 2 | 665
buserelin + cyproterone | buserelin | 2.3.4 | 1 | 224
leup/orch + cyproterone | leup/orch | 3.1.4 | 0 | 0
leuprolide + cyproterone | orchiectomy | 4.4.1 | 0 | 0
goserelin + cyproterone | orchiectomy | 4.4.2 | 0 | 0
buserelin + cyproterone | orchiectomy | 4.4.3 | 1 | 229
Comparison of Combination Regimens
LHRH-a + bicalutamide | LHRH-a + flutamide | 2a.1 | 1 | 813

Finally, for each principal reference cited in the monotherapy evidence tables, data also may have been derived from additional studies/citations, as can be seen in the following table:

Appendix II. Citation Key for Evidence Tables on Combined Androgen Blockade

For the Principal Study Cited In Evidence Table: | Data Also Were Derived from the Following Studies: ^a^
Zalcberg, Raghaven, Marshall et al., 1996
Williams, Asopa, Abel et al., 1990
Periti, Rizzo, Mazzei et al., 1995.
Ferrari, Castagnetti, Ferrari et al., 1993
Iversen, Christensen, Friis et al., 1990 | · Iversen, Rasmussen, Klarskov et al., 1993 · Iversen, 1990
Beland, Elhilali, Fradet et al., 1990a | · Beland, Elhilali, Fradet et al., 1988 · Beland, Elhilali, Fradet et al., 1990b · Beland, Elhilali, Fradet et al., 1987 · The Canadian Anandron Study Group, 1990 · Beland, Elhilali, Fradet et al., 1991 · Beland, 1991
Boccardo, Pace, Rubagotti et al., 1993
Thorpe, Azmatullah, Fellows et al., 1996
Robinson, Smith, Richards et al., 1995 | · Robinson, 1993 · Robinson, 1987 · Robinson, 1988 · Newling, Pavone Macaluse, Smith et al., 1992
Jorgensen, Tveter, and Jorgensen, 1993 | · Jorgensen, Muller, Kaalhus et al., 1995
Fourcade, Cariou, Colob et al., 1990
Di Silverio, Serio, D'Eramo et al., 1990 | · Di Silverio and Serio, 1990
Knonagel, Bolle, Hering et al., 1989
Namer, Toubol, Caty et al., 1990 | · Namer, Amiel, and Toubol, 1988
de Voogt, Klijn, Studer et al., 1990 | · Klijn, de Voogt, Studer et al., 1993
Dijkman, Janknegt, De Reijke et al., 1997 | · Janknegt, 1993 · Dijkman, Fernandez del Moral, Debruyne et al., 1995 · Janknegt, Abbou, Bartoletti et al., 1993
Tyrrell, Altwein, Klippel et al., 1991 | · Tyrrell, Altwein, Klippel et al., 1993 · Lunglmayr, 1989 · Jurincic, Horlbeck, and Klippel, 1991 · Jurincic Winkler, Horlbeck et al., 1992
Crawford, Eisenberger, McLeod et al., 1989 | · McLeod, Crawford, Blumenstein et al., 1992 · Crawford, Blumenstein, Goodman et al., 1990 · Benson, 1993 · Crawford, 1990a · Crawford, 1990b · Crawford and Allen, 1990 · Eisenberger, Crawford, McLeod et al., 1992 · Eisenberger, Crawford, Wolf et al., 1994 · Benson, Crawford, Eisenberger et al., 1991 · Crawford, Goodman, and Blumenstein, 1990 · Crawford and Nabors, 1991 · Crawford, 1994
Crawford, Kasimis, Gandara et al., 1990
Navratil, 1987
Brisset, Boccon-Gibod, Botto et al., 1987.
Ferrari, Castagnetti, Ferrari et al., 1996
Schulze, Kaldenhoff, and Senge 1988
Schellhammer, Sharifi, Block et al., 1997 | · Blackledge, Kolvenbag, and Nash, 1996 · Schellhammer, Sharifi, Block et al., 1996a · Soloway, Schellhammer, Sharifi et al., 1996 · Schellhammer, Vogelzang, Sharifi et al., 1996 · Kennealey, Vogelzang, Soloway et al., 1996 · Vogelzang, Schellhammer, Block et al., 1995 · Zerbib and Payan, 1996 · Schellhammer, Sharifi, Block et al., 1996b · Crawford, 1995 · Schellhammer, Sharifi, Block et al., 1995
Denis, Carnelro de Moura, Bono et al., 1993 | · Newling, Denis, and Vermeylen, 1993 · Keuppens, Whelan, Carneiro de Moura et al., 1993 · Keuppens, Denis, Smith et al., 1990 · Denis, Smith, De Moura et al., 1990 · Denis, Keuppens, Newling et al., 1990 · Denis, Robinson, Mahler et al., 1990 · Carvalho, de Moura, Denis et al., 1989 · Denis, Keuppens, Robinson et al., 1990 · Newling, Pavone Macaluse, Smith et al., 1992 · Denis, Smith, Carneiro de Moura et al., 1991
Klosterhalfen and Becker, 1987
Eisenberger, Blumenstein, Crawford et al., 1998 | · Eisenberger, Crawford, McLeod et al., 1997
Bono, DiSilverio, Robustelli della Cuna et al., 1998

a Where no additional studies are cited, the only study from which data were derived was the principal study

b Where no additional studies are cited, the only study from which data were derived was the principal study

c Where no additional studies are cited, the only study from which data were derived was the principal study

Appendix II. Abbreviation Key for Evidence Tables

% @ Endpt | | percentage of patients reaching endpoint
% ch | | percent change
% M1 | | percentage of patients with M1 disease
% PD | | percentage of patients with poorly differentiated tumor
% Sx | | percentage of patients with symptomatic disease
95% CI | | 95% confidence interval
ALT | | alanine aminotransferase
AST | | aspartate aminotransferase
bica | | bicalutamide
buser | | buserelin
CAB | | combined androgen blockade
CC | | comparison code
Comp Code | | comparison code
contin | | continuous
CV | | cardiovascular
Cx | | control group
cypr | | cyproterone
d | | day
d/c | | discontinued
DAPROCA | | Danish Prostate Cancer Group
DB? | | double-blind?
dec | | decreased
difs | | differences
Doc? | | withdrawals from enrollment documented?
EORTC | | European Organization for Research and Treatment of Cancer
f/u | | follow-up
fluta | | flutamide
GB | | Gehan-Breslow test
GI | | gastrointestinal
goser | | goserelin
grp | | group
GW | | Gehan-Wilcoxon test
GYN | | gynecomastia
HE | | hepatic
HF | | heart failure
HR | | hazard ratio
HT | | hormonal therapy
immed | | immediate
IN | | intranasal
ITT | | intention-to-treat analysis performed?
Leth | | lethal
leupr | | leuprolide
LHRH | | luteinizing hormone releasing hormone analog
LR | | log rank test
L-T | | life-threatening
MC | | Mantel-Cox test
Md | | median
Med | | median
MI | | myocardial infarction
Mn | | mean
mo | | month
Mod | | moderate
MRC | | Medical Research Council Prostate Cancer Working Party Investigators Group
N @R BL | | number of patients at risk at baseline
N Anlz | | number of patients analyzed
N C, T3-4 | | number of patients with stage C or T3-4 disease
N D1, N+ | | number of patients with stage D1 or node positive disease
N Enr | | number of patients enrolled
N Rand | | number of patients randomized
NCI SWOG/ECOG INT 0105 | | National Cancer Institute Southwest Oncology Group/Eastern Cooperative Oncology Group Intergroup Study 0101
nilut | | nilutamide
nonsignif | | nonsignificant
NPCP | | National Prostate Cancer Project
NSAA | | nonsteroidal antiandrogen
O/E | | observed to expected
Orch | | orchiectomy
os | | overall survival
PFS | | progression-free survival
pfs | | progression-free survival
plac | | placebo
PN | | pain
PONCAP | | Italian Prostate Cancer Project
pts | | patients
RE | | renal
RPMS | | Royal Postgraduate Medical School
RTOG | | Radiation Therapy Oncology Group
sc | | subcutaneous
Sev | | severe
SPCG | | Scandinavian Prostate Cancer Group
SR | | skin reaction
TIA | | transient ischemic attack
TTP | | time to disease progression
Tx | | treatment group
VACURG | | Veterans Administration Cooperative Urological Research Group
w/ | | with
WD | | withdrawal
wdl | | withdrawal
Westphalian PCSG | | Westphalian Prostate Cancer Study Group
wk | | week
XRT | | external beam radiation therapy
yr | | year

Evidence Table II.1. CAB: Interventions and Demographics

Trial | Comp Code | Control Intervention | Treatment Intervention | DB? | Doc? | ITT | N Enr | N Rnd Cx | N Anlz Cx | N Rnd Tx | N Anlz Tx | Md/ Mn Age Cx | Md/ Mn Age Tx | %M1 Cx | %M1 Tx | %PD Cx | %PD Tx | %Sx Cx | %Sx Tx
Zalcberg 1996 Australian Multicenter Randomized Trial | 1.1.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus flutamide 750 mg | yes | partial | some | 222 | 110 | 110 | 112 | 112 | 71 | 72 | 98% | 100% | NS | NS | NS | NS
Eisenberger 1997 NCI SWOG/ECOG INT-1015 | 1.1.0 | bilateral orchiectomy | bilateral orchiectomy plus flutamide 750 mg | yes | no | ? | 1387 | 681 | 681 | 690 | 690 | | | 100% | 100% | NS | NS | NS | NS
Beland 1990 ^a^ Canadian Anandron Study Group | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | yes | yes | some | 208 | 96 | 96 | 98 | 98 | 70 | 69 | 100% | 100% | NS | NS | NS | NS
Knonagel 1989 Swiss Multicenter Double-Blind Anandron Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | yes | no | none | 51 | 25 | 20 | 26 | 19 | 74 | 74 | 96% | 92% | NS | NS | 64% | 42%
Namer 1990 French Multicenter Single-Dose Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | yes | partial | none | 151 | 60 | 53 | 65 | 45 | 72 | 72 | 100% | 97% | 34% | 53% | 43% | 38%
Dijkman 1997 International Anandron CAB Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg 1 mo then 150 mg | yes | yes | some | 457 | 232 | 232 | 225 | 225 | 72 | 71 | 100% | 98% | 39% | 38% | 61% | 68%
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 150 mg | yes | partial | none | 195 | 43 | 43 | 46 | 46 | 72 | 73 | 88% | 91% | NS | NS | 42% | 61%
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | yes | partial | none | 195 | 43 | 43 | 38 | 38 | 72 | 70 | 88% | 97% | NS | NS | 42% | 45%
Williams 1990 Hammersmith/RPMS Trial (UK) | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 300 mg | no | yes | ? | 44 | 24 | 24 | 20 | 20 | 72 | 74 | 67% | 80% | 63% | 50% | NS | NS
Robinson 1995 EORTC Protocol 30805 | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 50 mg | no | partial | some | 351 | 110 | 110 | 111 | 111 | | | 100% | 100% | 36% | 36% | 56% | 59%
Jorgensen 1993 SPCG Study No. 2 | 1.4.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus cyproterone 150 mg | yes | partial | none | 294 | 136 | 136 | 137 | 137 | | | 100% | 100% | NS | NS | NS | NS
Klosterhalfen 1987 Hamburg Trial (Germany) | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 50 mg | no | no | ? | 78 | 16 | 16 | 26 | 26 | | | 100% | 100% | NS | NS | NS | NS
Crawford 1989 NCI Intergroup Trial | 2.1.1 | leuprolide 1 mg sc daily plus placebo | leuprolide 1 mg sc plus flutamide 750 mg | yes | partial | some | 617 | 300 | 300 | 303 | 303 | 67 | 67 | 100% | 100% | NS | NS | 77% | 78%
Ferrari 1996 Modena Leuprolide +/-- Flutamide Trial | 2.1.1 | leuprolide (dose?) IM 28 d; cyproterone 150 mg 3 wk | leuprolide IM (dose?) plus flutamide 750 mg | no | partial | none | 150 | 76 | 62 | 74 | 63 | 72 | 69 | 100% | 100% | NS | NS | NS | NS
Bono 1998 Italian Leurporelin Group Trial | 2.1.1 | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus flutamide 750 mg | no | yes | all | 277 | 120 | 120 | 121 | 121 | 70 | 67 | 49% | 54% | 31% | 39% | 39% | 43%
Crawford 1990 ^b^ North American Multicenter Trial | 2.1.2 | leuprolide plus placebo | leuprolide plus nilutamide | yes | no | none | 411 | 202 | 202 | 209 | 209 | | | 100% | 100% | NS | NS | NS | NS
Periti 1995 Italian Multicenter Trial | 2.1.2 | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus nilutamide 300 mg 1st mo, then 150 mg | yes | no | none | 126 | | | | | | | ? | ?
Boccardo 1993 PONCAP Trial | 2.2.1 | goserelin 3.6 mg sc 4 wk | goserelin 3.6 mg sc 4 wk plus flutamide 750 mg | no | yes | some | 373 | 186 | 186 | 187 | 187 | 74 | 73 | 68% | 62% | 30% | 25% | 68% | 73%
Fourcade 1990 French Multicenter Trial | 2.2.1 | goserelin 3.6 mg sc 28 d plus placebo | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | yes | no | all | 245 | 125 | 125 | 120 | 120 | 74 | 74 | 84% | 81% | 39% | 40% | NS | NS
Tyrrell 1991 International Prostate Cancer Study Group Trial | 2.2.1 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | no | partial | some | 589 | 284 | 284 | 287 | 287 | 73 | 72 | 58% | 56% | 16% | 12% | 62% | 59%
Thorpe 1996 UK Multi-Center CAB Trial with Cyproterone | 2.2.4 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 100 mg | no | yes | all | 525 | 175 | 175 | 175 | 175 | 70 | 72 | 100% | 100% | 18% | 18% | NS | NS
Di Silverio 1990 ^c^ Italian Multicenter Trial | 2.2.4 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 200 mg | no | no | ? | 328 | 163 | 156 | 165 | 159 | 71 | 71 | 100% | 100% | 13% | 11% | NS | NS
Ferrari 1993 Modena Buserelin CAB Trial | 2.3.1 | buserelin 1.5 mg sc 7 d then 1.2 mg IN | buserelin 1.5 mg sc 7 d then 1.2 mg IN plus flutamide 750 mg | no | partial | none | 122 | 62 | 46 | 60 | 62 | 69 | 72 | 100% | 100% | NS | NS | NS | NS
Navratil 1987 French Multi-center Buserelin Anandron CAB Trial | 2.3.2 | buserelin 0.5 mg sc plus placebo | buserelin 0.5 mg sc plus nilutamide 300 mg | yes | partial | some | 49 | 22 | 22 | 16 | 16 | 75 | 72 | 100% | 100% | NS | NS | 45% | 75%
de Voogt 1990 ^d^ EORTC Protocol 30843 | 2.3.4 | buserelin 1.5 mg sc, then 1.2 mg IN plus cyproterone 150 mg 2 wk | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | NA | no | ? | 367 | 113 | 113 | 111 | 111 | | | 100% | 100% | NS | NS | NS | NS
Schulze 1988 Westphalian PCSG CAB Trial | 3.2.1 | bilateral orchiectomy or goserelin 3.6 mg sc 4 wk | bilateral orchiectomy or goserelin 3.6 mg sc 4 wk plus flutamide 750 mg | NA | partial | some | 99 | 45 | 45 | 54 | 54 | | | | | NS | NS | NS | NS
Iversen 1990 ^e^ DAPROCA Trial # 86 | 4.1.2 | total or subcapsular bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | NA | partial | all | 264 | 133 | 133 | 129 | 129 | 72 | 72 | 89% | 93% | 63% | 50% | 38% | 38%
Denis 1993 ^f^ EORTC Protocol 30853 | 4.1.2 | bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | no | partial | none | 327 | 155 | 148 | 155 | 149 | | | 100% | 100% | 33% | 30% | 28% | 30%
De Voogt 1990 ^d^ EORTC Protocol 30843 | 4.4.3 | bilateral orchiectomy | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | NA | no | ? | 367 | 118 | 118 | 111 | 111 | | | 100% | 100% | NS | NS | NS | NS
Schellhammer 1997 Casodex Combination Trial | 2a.1 | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus flutamide 750 mg | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus bicalutamide 50 mg. | yes | yes | some | 813 | 409 | 409 | 404 | 404 | 70 | 70 | 100% | 98% | 36% | 33% | NS | NS

a Beland, Elhilali, Fradet et al., 1990a

b Crawford, Kasimis, Gandara et al., 1990

c di Silverio, Serio, D'Eramo et al., 1990

d de Voogt, Klijn, Studer et al., 1990

e Iversen, Christensen, Friis et al., 1990

f Denis, Carnelro de Moura, Bono et al., 1993

Evidence Table II.2. CAB: Overall Survival

Trial | CC | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | p value | Comment
Zalcberg 1996 Australian Multicenter Randomized Trial | 1.1.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus flutamide 750 mg | 110 | 112 | 31.0 | 23.0 | 88% | 74% | 60% | 48% | | | 71% | 72% | | 0.21
Eisenberger 1997 NCI SWOG/ECOG INT-1015 | 1.1.0 | bilateral orchiectomy | bilateral orchiectomy plus flutamide 750 mg | 685 | 697 | 29.9 | 33.5 | 85% | 86% | 62% | 63% | 28% | 32% | 70% | 67% | 0.91 (0.81, 1.01) | 0.14 | stratified LR
Beland 1990 ^a^ Canadian Anandron Study Group | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 96 | 98 | 18.9 | 24.3 | 72% | 77% | 38% | 49% | | | | | | 0.137 | GW p=0.121, #184 LR p=0.187
Namer 1990 French Multicenter Single-Dose Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 53 | 45 | | | 82% | 82% | | | | | | | | | no difference
Dijkman 1997 International Anandron CAB Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg 1mo then 150 mg | 232 | 225 | 23.6 | 27.3 | 77% | 83% | 51% | 60% | 18% | 27% | | | | 0.0326
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 150 mg | 43 | 46 | 24.0 | 22.0 | 83% | 82% | | | | | | | | | no significant difs among the 3 grps
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 43 | 38 | 24.0 | 22.0 | 83% | 79% | | | | | | | | | no significant difference
Williams 1990 Hammersmith/RPMS Trial (UK) | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 300 mg | 24 | 20 | | | 92% | 80% | 91% | 75% | | | | | | | nonsignifi- cant
Robinson 1995 EORTC Protocol 30805 | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 50 mg | 110 | 111 | 22.9 | 21.8 | 76% | 70% | 48% | 44% | 15% | 13% | 81% | 81% | | 0.751
Jorgensen 1993 SPCG Study No. 2 | 1.4.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus cyproterone 150 mg | 136 | 137 | 33.0 | 33.0 | 84% | 82% | 64% | 66% | | | | | | | no difference whatsoever
Klosterhalfen 1987 Hamburg Trial (Germany) | 1.4.0 | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 50 mg | 16 | 24 | 31.0 | 29.0 | 81% | 85% | 69% | 62% | 6% | 23% | | | | | crude survival
Crawford 1989 NCI Intergroup Trial | 2.1.1 | leuprolide 1 mg sc daily plus placebo | leuprolide 1 mg sc plus flutamide 750 mg | 300 | 303 | 29.0 | 35.0 | 84% | 90% | 59% | 66% | 23% | 26% | 83% | 81% | | 0.035 | #295; test NS; #534 (N deaths 180 cx, 149 tx), p#0.035
Bono 1998 Italian Leurporelin Group Trial | 2.1.1 | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus flutamide 750 mg | 120 | 121 | 31.6 | 32.1 | 95% | 95% | 79% | 78% | 10% | 15% | 69% | 69% | | 0.83 | nonsignif
Crawford 1990 ^b^ North American Multicenter Trial | 2.1.2 | leuprolide plus placebo | leuprolide plus nilutamide | 202 | 209 | 27.0 | 28.6 | | | 56% | 58% | | | | | | | nonsignif, med os reported but majority of pts had not died
Periti 1995 Italian Multicenter Trial | 2.1.2 | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus nilutamide 300 mg 1st mo, then 150 mg | 126 | | | | | | | | | | | | | | no significant difference after median followup of 30 mo
Boccardo 1993 PONCAP Trial | 2.2.1 | goserelin 3.6 mg sc 4 wk | goserelin 3.6 mg sc 4 wk plus flutamide 750 mg | 186 | 187 | 32.0 | 34.0 | 85% | 85% | 60% | 67% | | | 37% | 33% | | 0.4 | observed deaths O/E (1.07 cx, 0.92 tx)
Fourcade 1990 French Multicenter Trial | 2.2.1 | goserelin 3.6 mg sc 28 d plus placebo | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 125 | 120 | | | 80% | 78% | | | | | | | | 0.78 | at 15 mo med f/u
Tyrrell 1991 International Prostate Cancer Study Group Trial | 2.2.1 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 282 | 287 | 37.7 | 42.4 | 90% | 87% | 65% | 72% | 34% | 42% | | | | 0.14 | from #163; med f/u 56.2 mo; 95% CI for % ch: 4.78--31.88%
de Voogt 1990 ^c^ EORTC Protocol 30843 | 2.3.4 | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg 2 wk | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 113 | 111 | 25.0 | 25.0 | 78% | 88% | 53% | 52% | 17% | 14% | 87% | 86% | | 0.98
di Silverio 1990 ^d^ Italian Multicenter Trial | 2.2.4 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 200 mg | 156 | 159 | 30.1 | 23.8 | 83% | 81% | 63% | 49% | | | | | | 0.26
Iversen 1990 ^e^ DAPROCA Trial # 86 | 4.1.2 | total or subcapsular bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 133 | 129 | 27.6 | 22.7 | 77% | 80% | 58% | 47% | 20% | 20% | | | | 0.49 | from #157, med f/u 57 mo; nonsignif; N at risk every 10 mo
Denis 1993 ^f^ EORTC Protocol 30853 | 4.1.2 | bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 163 | 163 | 27.0 | 34.0 | 83% | 85% | 54% | 61% | 20% | 28% | 80% | 79% | 0.77 (0.60, 0.99) | 0.04
de Voogt 1990 ^c^ EORTC Protocol 30843 | 4.4.3 | bilateral orchiectomy | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 118 | 111 | 25.0 | 25.0 | 78% | 88% | 53% | 52% | 12% | 14% | 90% | 86% | | 0.98
Schellhammer 1997 Casodex Combination Trial | 2a.1 | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus flutamide 750 mg | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus bicalutamide 50 mg | 409 | 404 | 34.0 | 41.4 | 87% | 87% | 65% | 70% | | | 57% | 53% | 0.87 (0.72, 1.05) | 0.15

a Beland, Elhiladi, Fradet et al., 1990a

b Crawford, Kasimis, Gandara et al., 1990

c De Voogt, Klijn, Studer et al., 1990

d di Silvero, Serio, D'Eramo et al., 1990

e Iversen, Christensen, Frits et al., 1990

f Denis, Carnelro de Moura, Bono et al., 1990

Evidence Table II.3. CAB: Cancer-Specific Survival

Trial | CC | Control Intervention | Treatment Intervention | N@R BL Cx | N@R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | Test Result
Beland 1990 ^a^ Canadian Anandron Study Group | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 95 | 94 | 19.0 | 26.0 | 75% | 84% | 39% | 55% | | | | | | p = 0.048
Dijkman 1997 International Anandron CAB Trial | 1.2.0 | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg 1mo then 150 mg | 232 | 225 | 29.8 | 37.0 | 83% | 88% | 58% | 69% | 25% | 37% | | | | p = 0.013
Navratil 1987 French Multi-center Buserelin Anandron CAB Trial | 2.3.2 | buserelin 0.5 mg sc plus placebo | buserelin 0.5 mg sc plus nilutamide 300 mg | 22 | 16 | 17.0 | NA | 80% | 87% | | | | | 32% | 19% | | p = 0.579
de Voogt 1990 ^b^ EORTC Protocol 30843 | 2.3.4 | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg 2 wk | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 113 | 111 | 29.0 | 29.0 | 80% | 93% | 57% | 65% | 22% | 19% | 70% | 68% | | p = 0.91
Denis 1993 ^c^ EORTC Protocol 30853 | 4.1.2 | bilateral orchiectomy | goserelin 3.6 mg sc 28d plus flutamide 750 mg | 163 | 163 | 29.0 | 42.0 | 88% | 91% | 58% | 71% | 27% | 40% | | | 0.67 (0.49, 0.90) | p = 0.007
Iversen 1990 ^d^ DAPROCA Trial # 86 | 4.1.2 | total or subcapsular bilateral orchiectomy | goserelin 3.6 mg sc 28d plus flutamide 750 mg | 133 | 129 | 36.0 | 24.0 | 79% | 82% | 62% | 50% | 25% | 26% | | | | p = 0.59
de Voogt 1990 ^b^ EORTC Protocol 30843 | 4.4.3 | bilateral orchiectomy | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 118 | 111 | 33.0 | 29.0 | 88% | 93% | 65% | 65% | 18% | 19% | 67% | N 68% | | p = 0.91

a Beland, Elhiladi, Fradet et al., 1990a

b de Voogt, Klijn, Studer et al., 1990

c Denis, Carnelo de Moura, Bono et al., 1990

d Iversen, Christensen, Friis et al., 1990

Evidence Table II.4. CAB: Progression-Related Outcomes

Trial | CC | Outcome Name | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | p value | Comment
Eisenberger 1997 NCI SWOG/ECOG INT-1015 | 1.1.0 | PFS | bilateral orchiectomy | bilateral orchiectomy plus flutamide 750 mg | 685 | 697 | 18.8 | 20.4 | | | | | | | | | | 0.2100 | stratified LR
Beland 1990 ^a^ Canadian Anandron Study Group | 1.2.0 | TTP | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 96 | 98 | 11.7 | 12.4 | 47% | 53% | 21% | 22% | | | | | | 0.4620 | Wilcoxon p=0.152
Namer 1990 French Multicenter Single-Dose Trial | 1.2.0 | TTP | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 53 | 45 | | | 50% | 65% | | | | | | | | 0.0700 | 1 yr cited in table, fig and table differ
Dijkman 1997 International Anandron CAB Trial | 1.2.0 | PFS | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg 1mo then 150 mg | 208 | 202 | 14.7 | 21.2 | 67% | 77% | 34% | 46% | 13% | 21% | | | | 0.0024 | number withdrawals due to pro-gression (156 cx, 127 tx)
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | TTP | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 150 mg | 43 | 46 | 13.0 | 13.0 | 58% | 57% | | | | | | | | | no significant differences among the 3 grps
Brisset 1987 French Multicenter Two-Dose Anandron Trial | 1.2.0 | TTP | bilateral orchiectomy plus placebo | bilateral orchiectomy plus nilutamide 300 mg | 43 | 38 | 13.0 | 12.0 | 58% | 49% | | | | | | | | | no significant differences among the 3 grps
Williams 1990 Hammersmith/RPMS Trial (UK) | 1.4.0 | CPFR (TTP) | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 300 mg | 24 | 20 | | | 71% | 75% | 54% | 30% | | | | | | | nonsignificant
Robinson 1995 EORTC Protocol 30805 | 1.4.0 | PFS | bilateral orchiectomy | bilateral orchiectomy plus cyproterone 50 mg | 110 | 111 | 17.2 | 18.8 | 66% | 66% | 41% | 39% | 17% | 26% | 69% | 68% | | 0.4840
Jorgensen 1993 SPCG Study No. 2 | 1.4.0 | TTP | bilateral orchiectomy plus placebo | bilateral orchiectomy plus cyproterone 150 mg | 136 | 137 | 21.0 | 23.0 | 70% | 66% | 42% | 47% | | | | | | | no difference
Crawford 1989 NCI Intergroup Trial | 2.1.1 | PFS | leuprolide 1 mg sc daily plus placebo | leuprolide 1 mg sc plus flutamide 750 mg | 300 | 303 | 14.0 | 17.0 | 55% | 64% | 35% | 43% | 20% | 20% | 87% | 85% | | 0.039 | from #295, test NS, but # 534 (# failures 209 cx, 189 tx)
Ferrari 1996 Modena Leuprolide +/- Flutamide Trial | 2.1.1 | TTP | leuprolide (dose?) IM 28 d; cyproterone 150 mg 3 wk | leuprolide IM (dose?) plus flutamide 750 mg | 76 | 74 | 12.8 | 13.0 | | | | | | | | | | | nonsignificant
Crawford 1990 ^b^ North American Multicenter Trial | 2.1.2 | TTP | leuprolide plus placebo | leuprolide plus nilutamide | 202 | 209 | 24.0 | 25.0 | | | | | | | | | | | nonsignif, med pfs reported, majority of pts had not pro-gressed/died
Periti 1995 Italian Multicenter Trial | 2.1.2 | TTP | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus nilutamide 300 mg 1st mo, then 150 mg | 126 | | | | | | | | | | | | | | no significant difference after a median followup of 30 mo
Boccardo 1993 PONCAP Trial | 2.2.1 | PFS | goserelin 3.6 mg sc 4 wk | goserelin 3.6 mg sc 4 wk plus flutamide 750 mg | 186 | 187 | 18.0 | 24.0 | 63% | 70% | 41% | 50% | | | 54% | 47% | | 0.0900 | events O/E (1.12 cx, 0.88 tx)
Fourcade 1990 French Multicenter Trial | 2.2.1 | TTP | goserelin 3.6 mg sc 28 d plus placebo | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 125 | 120 | 12.8 | 12.0 | 58% | 50% | | | | | | | | 0.8000
Tyrrell 1991 International Prostate Cancer Study Group Trial | 2.2.1 | TTP | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 278 | 279 | 31.7 | 25.0 | 67% | 67% | 55% | 52% | | | | | | 0.7400 | med f/u 25 mo (#163 w/ med f/u 56.2 mo, p=0.74)
Thorpe 1996 UK Multi-Center CAB Trial with Cyproterone | 2.2.4 | TTP | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 100 mg | 175 | 175 | 11.5 | 10.8 | 46% | 42% | 31% | 21% | | | | | | 0.0160
di Silverio 1990 ^c^ Italian Multicenter Trial | 2.2.4 | TTP | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 200 mg | 156 | 159 | 24.9 | 22.1 | 67% | 68% | 50% | 44% | | | | | | 0.6800 | med pfs cited but differs w/ curve (55 wk cx, 54 wk tx)
Navratil 1987 French Multi-center Buserelin Anandron CAB Trial | 2.3.2 | TTP | buserelin 0.5 mg sc plus placebo | buserelin 0.5 mg sc plus nilutamide 300 mg | 22 | 16 | 10.0 | 13.0 | 48% | 63% | | | | | 45% | 38% | | 0.6560 | LR performed at 1 yr
de Voogt 1990 ^d^ EORTC Protocol 30843 | 2.3.4 | TTP | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg 2 wk | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 113 | 111 | 14.0 | 16.0 | 57% | 64% | 36% | 36% | 12% | 12% | 83% | 78% | | 0.2800 | overall comparison
Schulze 1988 Westphalian PCSG CAB Trial | 3.2.1 | PFS | bilateral orchiectomy or goserelin 3.6 mg sc 4 wk | orchiectomy or goserelin 3.6 mg sc 4 wk plus flutamide 750 mg | 45 | 54 | | | 56% | 63% | | | | | | | | | nonsignif
Iversen 1990 ^e^DAPROCA Trial # 86 | 4.1.2 | TTP | total or subcapsular bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 133 | 129 | 16.8 | 16.5 | 58% | 65% | 41% | 32% | | | | | | 0.6900
Denis 1993 ^f^ EORTC Protocol 30853 | 4.1.2 | TTP | bilateral orchiectomy | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 163 | 163 | 20.0 | 30.0 | 67% | 73% | 43% | 58% | 22% | 34% | 67% | 58% | 0.75 (0.58, 0.95) | 0.0090
de Voogt 1990 ^d^ EORTC Protocol 30843 | 4.4.3 | TTP | bilateral orchiectomy | (buserelin 1.5 mg sc, then 1.2 mg IN) plus cyproterone 150 mg contin. | 118 | 111 | 18.0 | 16.0 | 64% | 64% | 43% | 36% | 16% | 12% | 72% | 78% | | 0.2800 | overall comparison
Schellhammer 1997 Casodex Combination Trial | 2a.1 | TTP | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28d) plus flutamide 750 mg | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus bicalutamide 50 mg | 409 | 404 | 17.7 | 22.3 | 66% | 72% | 41% | 48% | | | 72% | 71% | 0.93 (0.79, 1.10) | 0.4100

Evidence Table II.5. CAB: Time to Treatment Failure

Trial | CC | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | p value | Comment
Crawford 1989 NCI Intergroup Trial | 2.1.1 | leuprolide 1 mg sc daily plus placebo | leuprolide 1 mg sc plus flutamide 750 mg | 300 | 303 | 13.9 | 16.9
Ferrari 1996 Modena Leuprolide +/- Flutamide Trial | 2.1.1 | leuprolide (dose?) IM 28 d; cyproterone 150 mg 3 wk | leuprolide IM (dose?) plus flutamide 750 mg | 76 | 74 | | | | | | | | | | | | | no statistical difference
Bono 1998 Italian Leurporelin Group Trial | 2.1.1 | leuprolide 3.75 mg sc 28 d | leuprolide 3.75 mg sc 28 d plus flutamide 750 mg | 120 | 121 | 20.2 | 20.3 | 91% | 89% | 61% | 59% | 29% | 33% | | | | 0.99
Tyrrell 1991 International Prostate Cancer Study Group Trial | 2.2.1 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus flutamide 750 mg | 282 | 287 | 13.0 | 11.6 | | | | | | | | | | 0.085
di Silverio 1990 ^c^ Italian Multicenter Trial | 2.2.4 | goserelin 3.6 mg sc 28 d | goserelin 3.6 mg sc 28 d plus cyproterone 200 mg | 156 | 159 | 12.4 | 10.8 | 52% | 47% | 37% | 27% | | | | | | 0.24
Ferrari 1993 Modena Buserelin CAB Trial | 2.3.1 | buserelin 1.5 mg sc 7 d then 1.2 mg IN | buserelin 1.5 mg sc 7 d then 1.2 mg IN plus flutamide 750 mg | 62 | 60 | 5.1 | 7.4 | | | | | | | | | | | no statistically significant difference
Schellhammer 1997 Casodex Combination Trial | 2a.1 | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus flutamide 750 mg | (leuprolide 7.5 mg sc 28 d or goserelin 3.6 mg sc 28 d) plus bicalutamide 50 mg | 409 | 404 | 11.9 | 16.7 | 50% | 58% | 18% | 46% | | | 24% | 18% | 0.749

a Beland, Elhiladi, Fradet et al., 1990a

b Crawford, Kasimis, Gandara et al., 1990

c di Silvero, Serio, D'Eramo et al., 1990

d De Voogt, Klijn, Studer et al., 1990

e Iversen, Christensen, Frits et al., 1990

f Denis, Carnelro de Moura, Bono et al., 1990

Table II.6. Cardiovascular Adverse Events, Monotherapy vs. Combined Androgen Blockade

| Cardiovascular Nonspecified | | | | Edema
| N Pts | % | N Studies | | N Pts | % | N Studies
Orch/LHRH | 570 | 4.0 | 4 | | 569 | 3.2 | 3
Orch/LHRH+NSAA | 387 | 4.9 | 3 | | 293 | 2.0 | 1
Orch/LHRH+Cyproterone | 175 | 1.7 | 1 | | 277 | 6.5 | 2
Any CAB | 562 | 3.9 | 4 | | 570 | 4.2 | 3

Table II.7. Endocrine Adverse Events, Monotherapy vs. Combined Androgen Blockade

| Hot Flashes | | | | Gynecomastia | | | Breast Pain/ Tenderness | | | Impotence | | | Decreased Libido
| N Pts | % | N Studies | | N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies
Orch/LHRH | 2594 | 40.1 | 16 | | 1441 | 9.4 | 10 | 649 | 7.7 | 5 | 515 | 71.1 | 5 | 519 | 70.1 | 5
Orch/LHRH+NSAA | 2789 | 40.0 | 12 | | 1987 | 7.0 | 9 | 1206 | 5.1 | 5 | 362 | 66.0 | 4 | 367 | 65.4 | 4
Orch/LHRH+Cyproterone | 488 | 52.7 | 4 | | 257 | 17.5 | 2 | 257 | 6.6 | 2 | 156 | 82.1 | 1 | 156 | 78.8 | 1
Any CAB | 3277 | 41.9 | 16 | | 2244 | 8.2 | 11 | 1463 | 5.4 | 7 | 518 | 70.8 | 5 | 523 | 69.4 | 5

Table II.8. Gastrointestinal Adverse Events, Monotherapy vs. Combined Androgen Blockade

| Gastrointestinal, Nonspecified | | | | Nausea/Vomiting | | | | Diarrhea | | | | GI pain
| N Pts | % | N Studies | | N Pts | % | N Studies | | N Pts | % | N Studies | | N Pts | % | N Studies
Orch/LHRH | 959 | 2.3 | 7 | | 1872 | 3.2-7.1 | 8 | | 1464 | 2.2 | 6 | | 124 | 1.6 | 2
Orch/LHRH+NSAA | 768 | 10.3 | 6 | | 1851 | 5.6-9.2 | 8 | | 1458 | 8.2 | 6 | | 122 | 7.4 | 2
Orch/LHRH+Cyproterone | 175 | 0.6 | 1 | | 0 | | 0 | | 0 | | 0 | | 0 | | 0
Any CAB | 943 | 8.5 | 7 | | 1851 | 5.6-9.2 | 8 | | 1458 | 8.2 | 6 | | 122 | 7.4 | 2

Table II.9. Hepatic Adverse Events, Monotherapy vs. Combined Androgen Blockade

| Hepatic, Nonspecified | | | | Increased Liver Enzymes
| N Pts | % | N Studies | | N Pts | % | N Studies
Orch/LHRH | 1197 | 1.3 | 4 | | 483 | 2.7 | 3
Orch/LHRH+NSAA | 2004 | 5.0 | 6 | | 474 | 6.8 | 3
Orch/LHRH+Cyproterone | 0 | | 0 | | 0 | | 0

Table II.10. Ophthalmologic Adverse Events, Monotherapy vs. Combined Androgen Blockade

| | | Ophthalmologic, Nonspecified
Orchiectomy | 407 | 5.4 | N Pts | % | N Studies
| | | | | 3
Orchiectomy+Nilutamide | | | 396 | 29.0
| | | 396 | 29.0 | 3

Table II.11. Adverse Events Leading to Withdrawal from Therapy, Pooled Results, Monotherapy vs. Combined Androgen Blockade

Treatment (tx) | N Studies | N tx | N WD tx | % WD tx
leupr 1 daily | 1 | 268 | 0 | 0.0%
goser 3.6 1 mo | 11 | 1679 | 33 | 2.0%
goser 10.8 3 mo | 2 | 77 | 1 | 1.3%
buser 0.4 | 1 | 72 | 3 | 4.2%
orch+nilut 150 | 2 | 271 | 38 | 14.0%
orch+nilut 300 | 3 | 209 | 24 | 11.5%
orch+cypr 150 | 1 | 102 | 3 | 2.9%
orch+cypr 300 | 1 | 20 | 2 | 10.0%
orch/LHRHa | 28 | 4275 | 82 | 1.9%
goser 3.6 1 mo+fluta 750 | 5 | 846 | 94 | 11.1%
orch/LHRHa+fluta 750 | 9 | 2804 | 233 | 8.3%
orch/LHRHa+bica 50 | 1 | 401 | 41 | 10.2%
orch/LHRHa+nilut 150/300 | 5 | 480 | 62 | 12.9%
orch/LHRHa+cypr 150/300 | 2 | 122 | 5 | 4.1%

Table II.12. Adverse Events Leading to Withdrawal from Therapy, Monotherapy vs. Combined Androgen Blockade, Randomized Trials

Comp Code | Study | Stage | cx | tx | N cx | N WD cx | % WD cx | comment cx | N tx | N WD tx | % WD tx | comment tx
1.1.0 | Eisenberger ^a^ | D2 | orch+placebo | orch+fluta 750 | 669 | 10 | 1.5% | | 667 | 33 | 4.9%
1.2.0 | Djikman ^b^ | D2 | orch+placebo | orch+nilut 150 | 232 | 21 | 9.1% | | 225 | 35 | 15.6%
1.2.0 | Namer ^c^ | D | orch+placebo | orch+nilut 300 | 78 | 1 | 1.3% | | 72 | 7 | 9.7%
1.2.0 | Beland ^d^ | D2 | orch+placebo | orch+nilut 300 | 97 | 1 | 1.0% | GI | 99 | 9 | 9.1% | 3 HF, 6 other
1.2.0 | Brisset | D | orch+placebo | orch+nilut 150 | 43 | 0 | 0.0% | | 46 | 3 | 6.5%
| | | | orch+nilut 300 | | | | | 38 | 8 | 21.1%
1.4.0 | Robinson ^e^ | D | orch | orch+cypr 150 | 101 | 4 | 4.0% | non-CV | 102 | 3 | 2.9% | 3 CV
| | | DES 1 | | 98 | 14 | 14.3% | 13 CV, 1 non-CV
1.4.0 | Williams | C+D | orch | orch+cypr 300 | 24 | 0 | 0.0% | | 20 | 2 | 10.0%
2.1.1 | Crawford ^f^ | D2 | leupr 1 daily | leupr 1 daily +fluta 750 | 268 | 0 | 0.0% | | 264 | 0 | 0.0%
2.2.1 | Boccardo | C+D | goser 3.6 1 mo | goser 3.6 1 mo +fluta 750 | 154 | 0 | 0.0% | | 150 | 21 | 14.0% | d/c fluta, 17 dec. fluta
2.2.1 | Fourcade | C+D | goser 3.6 1 mo +placebo | goser 3.6 1 mo +fluta 750 | 125 | 4 | 3.2% | unclear | 120 | 5 | 4.2% | d/c fluta, GI
2.2.1 | Tyrrell | C+D | goser 3.6 1 mo | goser 3.6 1 mo +fluta 750 | 293 | 3 | 1.0% | 1 CV, 1 HF, 1 other | 293 | 44 | 15.0% | 27 GI, 6 HE, 11 other
2.2.4 | Thorpe | D | goser 3.6 1 mo | goser 3.6 1 mo +cypr 300 | 175 | 7 | 4.0% | 2 CV, 1 SR, 4 other | 175 | 12 | 6.9% | 2 CV, 3 RE, 7 other
3.2.1 | Schulze | adv | orch/goser 3.6 1 mo | orch/goser 3.6 1 mo+fluta 750 | 45 | 0 | 0.0% | | 54 | 1 | 1.9% | GI
4.1.2 | Denis ^g^ | D2 | orch | goser 3.6 1 mo +fluta 750 | 163 | 0 | 0.0% | | 164 | 11 | 6.7% | 4 GI, 4 HE, 3 other
4.1.2 | Iversen ^h^ | C+D | orch | goser 3.6 1 mo +fluta 750 | | | | | 119 | 13 | 10.9%
2a.1 | Schellhammer ^I^ | D2 | goser 3.6 1 mo/ leupr 7.5 1 mo | goser 3.6 1 mo/ leupr 7.5 1 mo | 401 | 41 | 10.2% | 5 GI, 6 HE, 30 other | 407 | 66 | 16.2% | 33 GI, 10 HE, 23 other
| | | +bical 50 | +fluta 750

a Eisenberger, Blumenstein, Crawford et al., 1998

b Djikman, Janknegt, De Reijke et al., 1997

c Namer, Toubol, Caty et al., 1990

d Beland, Elhiladi, Fradet et al., 1990

e Robinson, Smith, Richards et al., 1995

f Crawford, Kasimis, Gandara et al., 1990

g Denis, Carnelro de Moura, Bono et al., 1993

h Iversen, Christensen, Friis et al., 1990

i Schellhammer, Sharifi, Block et al., 1997

Table II.13. Adverse Events Leading to Withdrawal from Therapy, Phase II Study

Study | Stage | tx | N | N Wdl | % Wdl | comment
Oosterlinck | C+D | fluta 750 | 75 | 5 | 6.7 | 3 HE, 1 GI, 1 GYN
1996 | C+D | orch/LHRHa+fluta 750 | 830 | 39 | 4.7 | 27 GI, 4 HE, 4 HF, 4
| | | | | | other

Table II.14. Adverse Events Reported in Package Inserts

Agent(s)/Dosage Form | | DES | Orch | Orch | Orch | Leupr daily | Leupr 1 mo | Leupr 3 mo | Leupr 4 mo | Goser 1 mo | Goser 3 mo | LHRHa +Plac | LHRHa +Fluta | LHRHa +Fluta | Orch +Nilut | Leupr +Plac | Leupr +Nilut | LHRHa +Bica
Total N | | 101 % | 24 % | 254 % | 232 % | 98 % | 56 % | 94 % | 49 % | 242 % | 157 % | 285 % | 294 % | 407 % | 225 % | 202 % | 209 % | 401 %
Cardiovascular System
| CHF | 5.0% | | 1.2% | | 1.0% | | | | 5.0%
| ECG changes/ischemia | 21.8% | | | | 19.4%
| chest pain | | | | | | | | | | | | | 4.9% | | 4.5% | 7.2% | 6.0%
| high blood pressure | 5.0% | | | 2.6% | 8.2% | | | | | | | | 4.4% | 5.3% | 9.9% | 9.1% | 5.2%
| peripheral edema | 29.7% | | | | 12.2% | | | | | | | | 6.9% | | 17.3% | 12.4% | 8.5%
| edema | | 20.8% | 7.9% | | | 12.5% | | 8.2% | 7.0%
| phlebitis/thrombosis | 9.9% | | | | 2.0%
Gastrointestinal System | | | 12.5% | | | | 26.8% | | 10.2%
| anorexia | 5.0% | | 2.0% | | 6.1% | | | | 5.0% | | | | | | 6.4% | 11.0%
| constipation | 8.9% | | | 3.9% | 7.1% | | | | | | | | 12.3% | 7.1% | 16.8% | 19.6% | 16.7%
| nausea | | | 2.0% | 6.0% | | | | | 5.0% | | | | 11.1% | 9.8% | 8.4% | 26.8% | 11.0%
| nausea/vomiting | 16.8% | | | | 5.1% | 5.4% | | | | | 10.2% | 10.9%
| vomiting | | | | | | | | | | | | | 4.9% | | 4.0% | 5.7% | 3.0%
| diarrhea | | | | | | | | | | | 3.9% | 11.9% | 24.1% | | | | 10.0%
| abdominal pain | | | | | | | | | | | | | 7.6% | | | 10.0% | 8.2%
Endocrine System
| gynecomastia | | | | | | | | | | 8.3% | 10.9% | 8.8% | 5.7% | | 11.9% | 10.5% | 4.7%
| gynecom/breast pain/tenderness | 62.4% | | | | 7.1% | 58.9%
| hot flashes | 11.9% | 8.3% | 53.1% | 22.4% | 56.1% | 5.4% | 58.5% | 46.9% | 62.0% | 63.7% | 56.8% | 60.9% | 49.6% | 28.4% | 59.4% | 66.5% | 48.9%
| impotence | 11.9% | | 16.1% | | 4.1% | | | | 18.2% | | 29.1% | 33.0% | 7.1% | | 12.9% | 11.0% | 5.0%
| loss of libido | | | 15.0% | | | | | | 21.1% | | 30.9% | 36.1% | | | 4.5% | 11.0%
Hepatic
| increased AST | | | | 3.9% | | | | | | | | | | 8.0% | 13.9% | 12.9%
| increased ALT | | | | 4.3% | | | | | | | | | | 7.6% | 8.9% | 9.1%
| increased AST/ALT | | | | | | | | | | | | | 9.8% | | | | 7.2%
Special Senses
| impaired adaptation to dark | | | | 1.3% | | | | | | | | | | 12.9% | 5.4% | 56.9%
| impaired adaptation to light | | | | | | | | | | | | | | | 1.0% | 7.7%
| chromotopsia | | | | | | | | | | | | | | | 0.0% | 8.6%
| abnormal vision | | | | 1.7% | | | | | | | | | | 6.7% | 4.5% | 6.2%

Evidence Table II.15. Analysis Data Set for 2-Year Hazard Rates for Total Mortality in Prostate Cancer Patients

Study # | Ln-Hazard | variance | orch | Orch/NSAA | LHRH | LHRH/NSAA | LHRH/cypro | Orch/cypro | Combined | 434 | 296 | 101 | 861 | 303 | 305 | 182 | 810 | 279 | 439 | 089 | 256 | 534 | 446 | 467 | 184 | 607 | 1500 | 565 | 1501
434 | -0.9241 | 0.0522 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
434 | -0.9241 | 0.1239 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
296 | -0.8068 | 0.0208 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
296 | -0.8782 | 0.0218 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
101 | -2.3612 | 0 .4633 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
101 | -1.2459 | 0.2014 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
861 | -0 .9914 | 0.2039 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
861 | -0.7381 | 0.1118 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
303 | -0.8068 | 0.0402 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
303 | -0.6993 | 0.0381 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
305 | -0.7721 | 0.0176 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
305 | -0.3378 | 0.0129 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
182 | -0.6075 | 0.0183 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
182 | -0.2810 | 0.0153 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
810 | -0.4842 | 0.0138 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
810 | -0.7046 | 0.0161 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
279 | -0.3093 | 0.0183 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
279 | -0.1973 | 0.0170 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
439 | -0.4543 | 0.0186 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
439 | -0.4543 | 0.0195 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
439 | -0.4248 | 0.0194 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
089 | -0.6717 | 0.0232 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
089 | -0.3103 | 0.0180 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
256 | -0.6717 | 0.0137 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
256 | -0.9151 | 0.0302 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
534 | -0.6394 | 0.0083 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
534 | -0.8782 | 0.0098 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
446 | -0.3955 | 0.0091 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
446 | -0.6717 | 0.1140 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0
467 | -0.8422 | 0.0103 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
467 | -1.1132 | 0.0126 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
184 | -0.0330 | 0.0182 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
184 | -0.3378 | 0.0209 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
607 | -0.9871 | 0.1372 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0
607 | -0.7519 | 0.1259 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0
1500 | -0.5897 | 0.0208 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
1500 | -0.6542 | 0.0208 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0
565 | -0.4843 | 0.0103 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
565 | -0.5419 | 0.0100 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0
1501 | -1.4451 | 0.0399 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1
1501 | -1.3925 | 0.0378 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1

orch: orchiectomy; DES: diethylstilbestrol; leup: leuprolide; goser: goserelin; buser: buserelin; flut: flutamide; bicalut: bicalutamide; cypro: cyproterone; LHRH: luteinizing hormone-releasing hormone; NSAAs: nonsteroidal antiandrogens

(Key to study numbers on next page)

Key to Study Numbers in Evidence Table II.15

Study # | Reference
89 | Zalcberg, Raghaven, Marshall et al., 1996
101 | Williams, Asopa, Abel et al., 1990
137 | Periti, Rizzo, Mazzei et al., 1995
164 | Ferrari, Castagnetti, Ferrari et al., 1993
182 | Iversen, Christensen, Friis et al., 1990
184 | Beland, Elhilali, Fradet et al., 1990a
256 | Boccardo, Pace, Rubagotti et al., 1993
278 | Thorpe, Azmatullah, Fellows et al., 1996
279 | Robinson, Smith, Richards et al., 1995
296 | Jorgensen, Tveter, and Jorgensen, 1993
303 | Fourcade, Cariou, Colob et al., 1990
305 | Di Silverio, Serio, D'Eramo et al., 1990
327 | Knonagel, Bolle, Hering et al., 1989
434 | Namer, Toubol, Caty et al., 1990
439 | de Voogt, Klijn, Studer et al., 1990
446 | Dijkman, Janknegt, De Reijke et al., 1997
467 | Tyrrell, Altwein, Klippel et al., 1991
534 | Crawford, Eisenberger, McLeod et al., 1989
565 | Crawford, Kasimis, Gandara et al., 1990
606 | Navratil, 1987
607 | Brisset, Boccon-Gibod, Botto et al., 1987
749 | Ferrari, Castagnetti, Ferrar et al., 1996
756 | Schulze, Kaldenhoff, and Senge, 1988
777 | Schellhammer, Sharifi, Block et al., 1997
810 | Denis, Carnelro de Moura, Bono et al., 1993
861 | Klosterhalfen and Becker, 1987
1500 | Eisenberger, Blumenstein, Crawford et al., 1998
1501 | Bono, DiSilverio, Robustelli della Cuna et al., 1998