# Appendix I: Evidence Tables for Monotherapies

The data summarized in Evidence Tables I-1 through I-7 are organized based on the specific comparisons made among the monotherapies, as listed below. The code number (left column) identifies each comparison. In the tables, trials are identified by first author's name and year of the principal report. The list below also provides the number of trials and the number of literature citations for each comparison (right column).

Appendix I.Coding Key

Code | Comparison | Available Reports
1.0 | orchiectomy versus DES | 3 trials; 15 citations
2.1 | orchiectomy versus leuprolide | no trials
2.2 | orchiectomy versus goserelin | 2 trials; 9 citations
2.3 | orchiectomy versus buserelin | 3 trials; 6 citations
3.1 | DES versus leuprolide | 1 trial; 8 citations
3.2 | DES versus goserelin | 3 trials; 6 citations
3.3 | DES versus buserelin | no trials
4.1 | orchiectomy or DES versus leuprolide | no trials
4.2 | orchiectomy or DES versus goserelin | no trials
4.3 | orchiectomy or DES versus buserelin | 1 trial; 2 citations
5.1 | orchiectomy versus flutamide | 1 trial; 1 citation
5.2 | orchiectomy versus nilutamide | no trials
5.3 | orchiectomy versus bicalutamide | 1 trial; 2 citations
5.4 | orchiectomy versus cyproterone | 2 trials; 2 citations
6.1 | DES versus flutamide | 2 trials; 3 citations
6.2 | DES versus nilutamide | no trials
6.3 | DES versus bicalutamide | no trials
6.4 | DES versus cyproterone | 3 trials; 11 citations
7.1 | orchiectomy or LHRH agonist versus flutamide | no trials
7.2 | orchiectomy or LHRH agonist versus nilutamide | no trials
7.3 | orchiectomy or LHRH agonist versus bicalutamide | 4 trials; 7 citations
7.4 | orchiectomy or LHRH agonist versus cyproterone | no trials
8.1 | goserelin versus cyproterone | 2 trials; 2 citations

Alternatively, the body of literature can be organized by the agents of interest: trials of LHRH agonists and trials of antiandrogens.

Agent | Control | Comparison Code | # Trials | N
LHRH Agonists
leuprolide | orchiectomy DES orch. or DES | 2.1 3.1 4.1 | 0 1 0 | 0 199 0
goserelin | orchiectomy DES orch. or DES | 2.2 3.2 4.2 | 2 3 0 | 608 580 0
buserelin | orchiectomy DES orch. or DES | 2.3 3.3 4.3 | 3 0 1 | 354 0 167
Antiandrogens
flutamide | orchiectomy DES orch or LHRH agonist | 5.1 6.1 7.1 | 1 2 0 | 104 132 0
nilutamide | any | 5.2 -- 7.2 | 0 | 0
bicalutamide | orchiectomy DES orch or LHRH agonist | 5.3 6.3 7.3 | 1 0 4 | 376 0 2,105
cyproterone | Orchiectomy DES orch or LHRH agonist LHRHa (buserelin) | 5.4 6.4 7.4 8.1 | 2 3 0 2 | 175 432 0 568
DES | Orchiectomy | 1.0 | 3 | 1,302

Finally, for each principal reference cited in the monotherapy evidence tables, data also may have been derived from additional studies/citations, as can be seen in the following table:

Appendix I. Citation Key for Evidence Tables on Monotherapy

For the Principal Study Cited In Evidence Table: | Data Also Were Derived from the Following Studies a:
Waymont, Lynch, Dunn et al., 1992 | - Emtage, Trethowan, Hilton et al., 1988; - Emtage, Trethowan, Kelly et al., 1989; - Peeling, 1989b
Kaisary, Tyrrell, Peeling et al., 1991 | - Ryan and Peeling, 1988; - Turkes, Peeling, and Griffiths 1987; - Kaisary, Ryan, Turkes et al., 1988; - Peeling, 1989a; - Turkes and Griffiths, 1989; - Peeling, 1989b
Lund and Rasmussen, 1988
Huben and Murphy, 1988 | - Klioze, Miller, and Spiro, 1988.
Iversen, Tyrrell, Kaisary et al., 1998
Thorpe, Azmatullah, Fellows et al., 1996
Robinson, Smith, Richards et al., 1995 | - Robinson, 1993; - Robinson, 1987; - Robinson, 1988; - Newling, Pavone Macaluse, Smith et al., 1992
Kaisary, Tyrrell, Beacock et al., 1995 | - Bales and Chodak, 1996
Iversen, 1994 | - Blackledge, 1996; - Kaisary, Tyrrell, Beacock et al., 1995; - Kaisary, 1994; - Cleary, Morrissey, and Oster, 1995; - Bales and Chodak, 1996
Moffat, 1990
Chang, Yeap, Davis et al., 1996 | - Chang, Yeap, Blum et al., 1992
de Voogt, Klijn, Studer et al., 1990 | - Klijn, de Voogt, Studer et al., 1993
Pavone-Macaluso, de Voogt, Viggiano et al., 1986 | - de Voogt, Smith, Pavone-Macaluso et al., 1986; - Pavone-Macaluso, Martinez-Pineiro, de Voogt et al., 1982; - Smith, Pavone-Macaluso, Viggiano et al., 1984; - Robinson, Smith, Macaluso et al., 1985; - Pavone-Macaluso, Ingargiola, de Voogt et al., 1987; - deVoogt, 1990
Peeling, 1984
The Leuprolide Study Group 1984 | - Garnick, Glode, Smith et al., 1985a; - Garnick, Glode, Smith et al., 1985b; - Seely, 1987; - Swanson and Garnick, 1987; - Garnick, 1986
Koutsilieris and Tolis, 1985
Citrin, Resnick, Guinan et al., 1991
Bruun and Frimodt-Moller, 1996
Iversen, Tveter, and Varenhorst, 1996 | - Bales and Chodak, 1996
Veterans Administration Co-operative Urological Research Group, 1967 | - Jordan, Blackard, and Byar, 1977; - Anon, 1967; - Blackard, Byar, and Jordan, 1973; - Byar and Corle, 1988
Ostri, Bonnesen, Nilsson et al., 1991
Chodak, Sharifi, Kasimis et al., 1995 | - Bales and Chodak, 1996
Vogelzang, Chodak, Soloway et al., 1995 | - Soloway, Chodak, Vogelzang et al., 1991
Blackard, Byar, and Jordan, 1973
Boccon-Gibod, Fournier, Bottet et al., 1997

a Where no additional studies are cited, the only study from which data were derived was the principal study

Appendix I. Abbreviation Key for Evidence Tables

% @ Endpt | | percentage of patients reaching endpoint
% ch | | percent change
% M1 | | percentage of patients with M1 disease
% PD | | percentage of patients with poorly differentiated tumor
% Sx | | percentage of patients with symptomatic disease
95% CI | | 95% confidence interval
ALT | | alanine aminotransferase
AST | | aspartate aminotransferase
bica | | bicalutamide
buser | | buserelin
CAB | | combined androgen blockade
CC | | comparison code
Comp Code | | comparison code
contin | | continuous
CV | | cardiovascular
Cx | | control group
cypr | | cyproterone
d | | day
d/c | | discontinued
DAPROCA | | Danish Prostate Cancer Group
DB? | | double-blind?
dec | | decreased
difs | | differences
Doc? | | withdrawals from enrollment documented?
EORTC | | European Organization for Research and Treatment of Cancer
f/u | | follow-up
fluta | | flutamide
GB | | Gehan-Breslow test
GI | | gastrointestinal
goser | | goserelin
grp | | group
GW | | Gehan-Wilcoxon test
GYN | | gynecomastia
HE | | hepatic
HF | | heart failure
HR | | hazard ratio
HT | | hormonal therapy
immed | | immediate
IN | | intranasal
ITT | | intention-to-treat analysis performed?
Leth | | lethal
leupr | | leuprolide
LHRH | | luteinizing hormone releasing hormone analog
LR | | log rank test
L-T | | life-threatening
MC | | Mantel-Cox test
Md | | median
Med | | median
MI | | myocardial infarction
Mn | | mean
mo | | month
Mod | | moderate
MRC | | Medical Research Council Prostate Cancer Working Party Investigators Group
N @R BL | | number of patients at risk at baseline
N Anlz | | number of patients analyzed
N C, T3-4 | | number of patients with stage C or T3-4 disease
N D1, N+ | | number of patients with stage D1 or node positive disease
N Enr | | number of patients enrolled
N Rand | | number of patients randomized
NCI SWOG/ECOG INT 0105 | | National Cancer Institute Southwest Oncology Group/Eastern Cooperative Oncology Group Intergroup Study 0101
nilut | | nilutamide
nonsignif | | nonsignificant
NPCP | | National Prostate Cancer Project
NSAA | | nonsteroidal antiandrogen
O/E | | observed to expected
Orch | | orchiectomy
os | | overall survival
PFS | | progression-free survival
pfs | | progression-free survival
plac | | placebo
PN | | pain
PONCAP | | Italian Prostate Cancer Project
pts | | patients
RE | | renal
RPMS | | Royal Postgraduate Medical School
RTOG | | Radiation Therapy Oncology Group
sc | | subcutaneous
Sev | | severe
SPCG | | Scandinavian Prostate Cancer Group
SR | | skin reaction
TIA | | transient ischemic attack
TTP | | time to disease progression
Tx | | treatment group
VACURG | | Veterans Administration Cooperative Urological Research Group
w/ | | with
WD | | withdrawal
wdl | | withdrawal
Westphalian PCSG | | Westphalian Prostate Cancer Study Group
wk | | week
XRT | | external beam radiation therapy
yr | | year

Evidence Table I.1. Monotherapies: Interventions and Demographics

Trial | Comp Code | Control Intervention | Treatment Intervention | DB? | WDL Doc? | ITT | N Enr | N Rnd Cx | N Anlz Cx | N Rnd Tx | N Anlz Tx | Md/ Mn Age Cx | Md/ Mn Age Tx | %M1 Cx | %M1 Tx | %PD Cx | %PD Tx | %Sx Cx | %Sx Tx
Robinson 1995 EORTC Protocol 30805 (Europe) | 1.0 | bilateral total or subcapsular orchiectomy | diethylstilbestrol 1 mg/day | NA | yes | all | 351 | 110 | 110 | 107 | 107 | | | 100% | 100% | 36% | 36% | 56% | 59%
VACURG 1967 VACURG Trial, Stage III Patients | 1.0 | orchiectomy plus placebo | diethylstilbestrol 5 mg/day | NA | yes | all | 531 | 266 | 266 | 265 | 265 | | | 0% | 0% | NS | NS | NS | NS
Blackard 1973 VACURG Trial, stage IV patients | 1.0 | bilateral orchiectomy plus placebo | diethylstilbestrol 5 mg/day | NA | yes | all | 414 | 203 | 203 | 211 | 211 | | | NA | NA | NS | NS | NS | NS
Peeling 1984 British Prostate Group Trial | 1.0 | bilateral total or subcapsular orchiectomy | diethylstilbestrol 3 mg/day | NA | yes | none | 205 | 70 | 68 | 71 | 65 | | | 100% | 100% | NS | NS | NS | NS
Kaisary 1991 British Prostate Study Group | 2.2 | orchiectomy | goserelin 0.25 mg/day or 3.6 mg/28d | NA | yes | some | 358 | 163 | 144 | 162 | 148 | 72.5 | 71.8 | 100% | 100% | 19% | 14% | 40% | 42%
Vogelzang, Chodek 1995 ; Zoladex Prostate Study Group (US) | 2.2 | orchiectomy | goserelin 3.6 mg/28d | NA | yes | some | 283 | 145 | 145 | 138 | 138 | 69 | 69 | 100% | 100% | 32% | 35% | NS | NS
De Voogt, Klijn et al., 1990 EORTC Protocol 30843 (Europe) | 2.3 | orchiectomy | buserelin 0.5 mg/d sq 1 wk then 0.4 mg/d IN plus cyproterone 50 mg/d 2 wk | NA | no | ? | 367 | 108 | 108 | 99 | 99 | | | 100% | 100% | NS | NS | 58% | 52%
Koutsilieris 1985 McGill Trial | 2.3 | orchiectomy | buserelin 0.05 mg sc/ 1.5 mg sc/ 1.0 mg IN | NA | no | none | 29 | 9 | 6 | 20 | 13 | | | 67% | 70% | NS | NS | 100% | 43%
Bruun 1996M Danish Buserelin Study Group | 2.3 | subcapsular bilateral orchiectomy | buserelin 1.5 mg sc 7d, then 1.2 mg IN | NA | yes | none | 126 | 46 | 38 | 72 | 57 | 74.5 | 71.7 | 100% | 100% | NS | NS | 54% | 54%
Leuprolide Study Group 1984 (North America) | 3.1 | diethylstilbestrol 3 mg/day | leuprolide 1 mg/day sc | no | partial | none | 199 | 101 | 95 | 98 | 93 | 71 | 69 | 100% | 100% | NS | NS | 58% | 51%
Waymont 1992 West Midlands Zoladex vs DES Trial (UK) | 3.2 | diethylstilbestrol 3 mg/day | goserelin 3.6 mg/28d | no | partial | some | 250 | 126 | 126 | 124 | 124 | 72.6 | 72.4 | 67% | 74% | 33% | 36% | 42% | 47%
Moffat 1990 UK Multicenter Trial | 3.2 | diethylstilbestrol 3 mg/day | goserelin 3.6 mg/28d | no | no | some | 372 | 33 | 33 | 230 | 230 | | | 0% | 0% | NS | NS | NS | NS
Citrin 1991 American Multicenter Trial | 3.2 | diethylstilbestrol 3 mg/day | goserelin 3.6 mg/28d | no | yes | some | 67 | 19 | 19 | 48 | 48 | 68 | 70 | 100% | 100% | 47% | 38% | NS | NS
Huben 1988 NPCP Protocol 1700/1700B (US) | 4.3 | orchiectomy or diethylstilbestrol 3 mg/day | buserelin 1.5 mg/d 7d, then 0.2 mg sc/1.2 mg IN daily | NA | yes | none | 167 | 56 | 55 | 111 | 110 | | | 100% | 100% | NS | NS | 70% | 69%
Boccon-Gibod 1997 French multi-center trial | 5.1 | bilateral total or subcapsular orchiectomy | flutamide 750 mg/day | NA | yes | some | 104 | 50 | 44 | 54 | 44 | 73.8 | 72.3 | 100% | 100% | NS | NS | NS | NS
Iversen 1996 Scandinavian Casodex Cooperative Group Study 0301 | 5.3 | bilateral orchiectomy | bicalutamide 50 mg/day | NA | yes | some | 376 | 190 | 153 | 186 | 153 | 70.3 | 71.5 | 100% | 100% | NS | NS | 48% | 39%
Peeling 1984 British Prostate Group Trial | 5.4 | bilateral total or subcapsular orchiectomy | cyproterone 300 mg/day | NA | yes | none | 205 | 70 | 68 | 64 | 60 | | | 100% | 100% | NS | NS | NS | NS
Ostri 1991 Copenhagen Cyproterone Trial | 5.4 | subcapsular orchiectomy | cyproterone 100 mg/day | NA | yes | none | 41 | 20 | 19 | 21 | 18 | 74.5 | 71 | 100% | 100% | NS | NS | 100% | 100%
Lund 1988 Copenhagen Flutamide Trial | 6.1 | diethylstilbestrol 3 mg/day | flutamide 750 mg/day | no | yes | all | 40 | 20 | 20 | 20 | 20 | 70.7 | 70.4 | 75% | 80% | 45% | 35% | 40% | 40%
Chang 1996 ECOG Trial (US) | 6.1 | diethylstilbestrol 3 mg/day | flutamide 750 mg/day | yes | yes | some | 92 | 48 | 48 | 44 | 44 | 67 | 68 | 100% | 100% | NS | NS | 43% | 56%
Moffat 1990 UK Multicenter Trial | 6.4 | diethylstilbestrol 3 mg/day | cyproterone 300 mg/day | no | no | some | 372 | 33 | 33 | 109 | 109 | | | 0% | 0% | NS | NS | NS | NS
Pavone- Macaluso 1986 EORTC protocol 30761 (Europe) | 6.4 | diethylstilbestrol 3 mg/day | cyproterone 250 mg/day | no | yes | some | 155 | 73 | 64 | 82 | 75 | | | 52% | 59% | 22% | 19% | 24% | 16%
Peeling 1984 British Prostate Group Trial | 6.4 | diethylstilbestrol 3 mg | cyproterone 300 mg/day | NA | yes | none | 205 | 71 | 65 | 64 | 60 | | | 100% | 100% | NS | NS | NS | NS
Kaisary 1995 Casodex Study Group Trial 0302 (Europe) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg/28d | bicalutamide 50 mg/day | no | yes | some | 304 | 154 | 154 | 150 | 150 | 72.1 | 71.9 | 99% | 100% | 37% | 35% | NS | NS
Iversen 1994 International Casodex Studies 0306/0307 (stage M1) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg/28d | bicalutamide 150 mg/day | NA | yes | some | 805 | 268 | 268 | 537 | 537 | 73 | 72 | 100% | 100% | NS | NS | NS | NS
Chodak 1995 Casodex study 0303 (US and Canada) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg/28d | bicalutamide 50 mg/day | no | yes | some | 516 | 257 | 257 | 259 | 259 | 70.9 | 69.6 | 100% | 100% | 45% | 48% | 57% | 59%
Iversen 1998 International Casodex studies 0306/0307 (stage M0) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg/28d | bicalutamide 150 mg/day | NA | yes | all | 480 | 160 | 160 | 320 | 320 | 73.5 | 73.1 | 0% | 0% | 28% | 25% | NS | NS
Thorpe 1996 UK Multi-Center Trial | 8.1 | goserelin 3.6 mg/28d | cyproterone 300 mg/day | no | yes | all | 525 | 175 | 175 | 175 | 175 | 70 | 72 | 100% | 100% | 18% | 18% | NS | NS
Moffat 1990 UK Multicenter Trial | 8.1 | goserelin 3.6 mg/28d | cyproterone 300 mg/day | no | no | some | 372 | 230 | 230 | 109 | 109 | | | 0% | 0% | NS | NS | NS | NS

Evidence Table I.2. Monotherapies: Overall Survival

Trial | CC | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | Stat Test | p value | Comment
Robinson 1995 EORTC Protocol 30805 (Europe) | 1.0 | bilateral total or subcapsular orchiectomy | diethylstilbestrol 1 mg | 110 | 107 | 22.9 | 25.1 | 76% | 77% | 48% | 55% | 15% | 17% | 81% | 79% | | LR | 0.751
VACURG 1967 VA Cooperative Urology Group (Stage III Patients) | 1.0 | orchiectomy plus placebo | diethylstilbestrol 5 mg | 266 | 265 | 67.0 | 60.0 | 89% | 86% | 77% | 73% | 53% | 49% | | | | | | orch signif better than DES at 1 yr and 4 yr
Blackard 1973VACURG Trial (stage IV patients) | 1.0 | bilateral orchiectomy plus placebo | diethylstilbestrol 5 mg | 203 | 211 | 30.0 | 33.0 | 78% | 77% | 57% | 59% | 25% | 25% | | | | | | no differences
Kaisary 1991 British Prostate Study Group | 2.2 | orchiectomy | goserelin 0.25 mg daily/ 3.6 mg 28d | 144 | 148 | 23.9 | 26.4 | 78% | 78% | 51% | 55% | | | 62% | 57% | | LR | 0.33
Vogelzang, Chodak et al., 1995; Zoladex Prostate Study Group (US) | 2.2 | orchiectomy | goserelin 3.6 mg 28d | 145 | 138 | 31.3 | 27.4 | 93% | 79% | 63% | 59% | 27% | 27% | | | 1.12 (0.85, 1.49) | Cox PH | 0.42
de Voogt, Klijn et al., 1990 EORTC Protocol 30843 (Europe) | 2.3 | orchiectomy | buserelin plus short-term cyproterone 150 mg | 118 | 113 | 25.0 | 25.0 | 78% | 78% | 53% | 53% | 12% | 17% | 90% | 87% | | LR | 0.98
Bruun 1996 Danish Buserelin Study Group | 2.3 | subcapsular bilateral orchiectomy | buserelin 1.5 mg sc 7d, then 1.2 mg IN | 46 | 72 | | | 71% | 76% | | | | | | | | LR | 0.4
Koutsilieris 1985 McGill Trial | 2.3 | orchiectomy | buserelin 0.05 mg sc/1.5 mg sc/1.0 mg IN | 6 | 13 | | | 83% | 85% | 50% | 46% | | | | | | | | crude survival; no statistical analysis reported
Leuprolide Study Group 1984 (North America) | 3.1 | diethyl-stilbestrol 3 mg | leuprolide 1 mg sc | 99 | 94 | 33.8 | 31.3 | 77% | 88% | 64% | 61% | | | 57% | 57% | | G-B/ M-C | 0.58
Waymont 1992 West Midlands Zoladex vs DES Trial (UK) | 3.2 | diethyl-stilbestrol 3 mg | goserelin 3.6 mg 28d | 126 | 124 | 27.7 | 27.4 | 79% | 75% | 57% | 57% | | | 64% | 68% | | LR chi sq | 0.88
Citrin 1991 American Multicenter Trial | 3.2 | diethyl-stilbestrol 3 mg | goserelin 3.6 mg 28d | 19 | 48 | | | 84% | 89% | 68% | 63% | | | | | 1.27 (0.47, 3.43) | | 0.6
Huben 1988 NPCP Protocol 1700/1700B (US) | 4.3 | orchiectomy or diethyl-stilbestrol 3 mg | buserelin 1.5 mg 7d, then 0.2 sc/1.2 mg in | 55 | 110 | | | 86% | 85% | 78% | 73% | | | 20% | 22% | | LR | | nonsignif- icant
Boccon-Gibod 1997 French multi-center trial | 5.1 | bilateral total or subcapsular orchiectomy | flutamide 750 mg | 50 | 54 | | | | | | | | | | | | | | no difference in overall survival at 69 mo
Iversen 1996 Scandinavian Casodex Cooperative Group Study 0301 | 5.3 | bilateral orchiectomy | bicalutamide 50 mg | 190 | 186 | 26.8 | 18.5 | 87% | 78% | 57% | 43% | | | 8% | 17% | 1.76 (1.27, 2.44) | Cox PH | 0.0007
Ostri 1991 Copenhagen Cyproterone Trial | 5.4 | subcapsular orchiectomy | cyproterone 100 mg | 19 | 18 | 15.0 | 9.0 | 62% | 43% | 34% | 17%
Lund 1988 Copenhagen Flutamide Trial | 6.1 | diethylstil-bestrol 3 mg | flutamide 750 mg | 20 | 20 | | | 95% | 100%
Chang 1996 ECOG Trial (US) | 6.1 | diethylstil-bestrol 3 mg | flutamide 750 mg | 48 | 44 | 43.2 | 28.5 | 95% | 88% | 81% | 66% | 39% | 15% | | | | LR | 0.009 | p=0.04 for eligible pts
Pavone- Macaluso 1986 EORTC protocol 30761 (Europe) | 6.4 | diethylstilbestrol 3 mg | cyproterone 250 mg | 63 | 75 | 40.0 | 38.0 | 80% | 86% | 64% | 65% | 36% | 28% | 51% | 55% | | LR | 0.52
Kaisary 1995 Casodex Study Group Trial 0302 (Europe) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 50 mg | 154 | 150 | 24.3 | 24.6 | 79% | 75% | 54% | 52% | | | 38% | 42% | 1.34 (0.94, 1.95) | Cox PH
Iversen 1994 International Casodex studies 0306/0307 (stage M1) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 150 mg | 268 | 537 | 25.6 | 24.2 | 85% | 80% | 59% | 53% | | | | | 1.30 (1.04, 1.64) | Cox PH | 0.02
Iversen 1998 International Casodex studies 0306/0307 (stage M0) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 150 mg | 160 | 320 | 53.4 ^a^ | | 94% | 94% | 81% | 88% | | | 30% | 31% | 0.93 (0.66, 1.31) | Cox PH | 0.67
Chodak 1995 Casodex study 0303 (US and Canada) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 50 mg | 257 | 259 | | | 86% | 84% | | | | | 35% | 39% | 1.29 (0.96, 1.72) | Cox PH | 0.09

a Median not yet reached at last analysis

Evidence Table I.3. Monotherapies: Progression-free Survival

Trial | Out-come Name | CC | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95% CI | TestResult | Comment
Robinson 1995 EORTC Protocol 30805 (Europe) | PFS | 1.0 | bilateral total or subcapsular orchiectomy | diethylstilbestrol 1 mg | 110 | 107 | 17.2 | 25.1 | 66% | 66% | 41% | 54% | 17% | 26% | 69% | 54% | | 0.484
Vogelzang, Chodak 1995 Zoladex Prostate Study Group (US) | TTP | 2.2 | orchiectomy | goserelin 3.6 mg 28d | 83 | 81 | | | 46% | 54% | | | | | 23% | 28%
Bruun 1996 Danish Buserelin Study Group | TTP | 2.3 | subcapsular bilateral orchiectomy | buserelin 1.5 mg sc 7d, then 1.2 mg IN | 38 | 57 | | | 34% | 44% | | | | | | | | | crude progression-free rate
De Voogt, Klijn 1990 EORTC Protocol 30843 (Europe) | TTP | 2.3 | orchiectomy | buserelin plus short-term cyproterone 150 mg | 118 | 113 | 18.0 | 14.0 | 64% | 57% | 43% | 36% | | | 72% | 83% | | 0.28 | overall comparison
Leuprolide Study Group 1984 (North America) | TTP | 3.1 | diethylstilbestrol 3 mg | leuprolide 1 mg sc | 80 | 79 | 14.0 | 13.8 | 65% | 60% | | | | | | | | 0.37 | GB (.47-MC; % cens:79 cx, 53 tx)
Huben 1988 NPCP Protocol 1700/1700B (US) | PFS | 4.3 | orchiectomy or diethylstilbestrol 3 mg | buserelin 1.5 mg 7d, then 0.2 sc/1.2 mg IN | 55 | 110 | 20.0 | 12.6 | 70% | 53% | 42% | 28% | | | 45% | 66% | | <0.05
Boccon-Gibod 1997 French multi-center trial | TTP | 5.1 | bilateral total or subcapsular orchiectomy | flutamide 750 mg | 42 | 44 | 12.2 | 13.0 | | | | | | | 86% | 93% | | 0.9
Iversen 1996 Scandinavian Casodex Cooperative Group Study 0301 | TTP | 5.3 | bilateral orchiectomy | bicalutamide 50 mg | 153 | 153 | | | | | | | | | 36% | 52% | 2.34 (1.62, 3.39) | | significant
Ostri 1991 Copenhagen Cyproterone Trial | TTP | 5.4 | subcapsular orchiectomy | cyproterone 100 mg | 19 | 18 | 9.0 | 11.0 | | | | | | | | | | | no significant difference
Lund 1988 Copenhagen Flutamide Trial | CPFR | 6.1 | diethylstilbestrol 3 mg | flutamide 250 mg | 20 | 20 | | | 55% | 70%
Pavone- Macaluso 1986 EORTC protocol 30761 (Europe) | TTP | 6.4 | diethylstilbestrol 3 mg | cyproterone 250 mg | 63 | 74 | 28.0 | 20.0 | 73% | 54% | 52% | 42% | 19% | 12% | 48% | 53% | | 0.123
Iversen 1994 International Casodex Studies 0306/0307 (stage M1) | TTP | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 150 mg | 268 | 537 | 16.1 | 12.0 | 62% | 50% | 35% | 23% | | | | | 1.44 (1.197, 1.732) | 0.0001 | 69% of all pts had progressed at last follow-up
Iversen 1994 International Casodex Studies 0306/0307 (stage M0) | TTP | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 150 mg | 160 | 320 | 27.4 34.6 | 44.9 30.2 | | | | | | | 56% | 60% | 0.58 (0.35, 0.96); 1.15 (0.76, 1.75 | 0.033 0.0471 | studies 0306 and 0307 report opposite results
Kaisary 1995 Casodex Study Group Trial 0302 (Europe) | TTP | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 50 mg | 126 | 119 | 10.4 | 8.6 | 36% | 32% | | | | | 45% | 45% | 1.14 (0.78, 1.67)
Chodak 1995 Casodex study 0303 (US and Canada) | TTP | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28d | bicalutamide 50 mg | 243 | 243 | 16.6 | 11.8 | 67% | 49% | | | | | 33% | 43% | 1.6 (1.19, 2.15) | 0.002
Thorpe 1996 UK Multi-Center Trial | TTP | 8.1 | goserelin 3.6 mg 28d | cyproterone 300 mg | 175 | 175 | 11.4 | 7.4 | 46% | 36% | 31% | 20% | | | | | | 0.016

Evidence Table I.4. Monotherapies: Time to Treatment Failure

Trial | CC | Control Intervention | Treatment Intervention | N @R BL Cx | N @R BL Tx | Med (mo) Cx | Med (mo) Tx | 1 yr Cx | 1 yr Tx | 2 yr Cx | 2 yr Tx | 5 yr Cx | 5 yr Tx | %@ Endpt Cx | %@ Endpt Tx | HR 95%CI | Statistical Test | p value | Comment
Kaisary 1991 British Prostate Study Group | 2.2 | orchiectomy | goserelin 0.25 mg daily/ 3.6 mg 28 d | 144 | 148 | 9.3 | 6.2 | 35% | 38% | | | | | | | | LR | 0.52
Vogelzang, Chodek 1995 Zoladex Prostate Study Group (US) | 2.2 | orchiectomy | goserelin 3.6 mg 28 d | 145 | 138 | 12.2 | 12.0 | 54% | 54% | 28% | 28% | | | | | | Cox PH | 0.99
Leuprolide Study Group 1984 (North America) | 3.1 | diethylstilbestrol 3 mg | leuprolide 1 mg sc | 99 | 94 | 16.4 | 14.3 | 55% | 63% | 44% | 33% | | | | | | | | comparable
Waymont 1992 West Midlands Zoladex vs DES Trial (UK) | 3.2 | diethylstilbestrol 3 mg | goserelin 3.6 mg 28 d | 126 | 124 | 11.4 | 14.5 | 48% | 58% | 24% | 35% | | | 58% | 48% | | LR chi sq | 0.06
Citrin 1991 American Multicenter Trial | 3.2 | diethylstilbestrol 3 mg | goserelin 3.6 mg 28 d | 19 | 48 | 9.7 | 16.7 | 43% | 63% | 36% | 32% | | | | | 0.72 (0.37, 3.44) | Cox PH | 0.3
Iversen 1996 Scandinavian Casodex Cooperative Group Study 0301 | 5.3 | bilateral orchiectomy | bicalutamide 50 mg | 153 | 153 | | | | | | | | | 33% | 56% | 2.24 (1.58, 3.18) | Cox PH | | significant
Lund 1988 Copenhagen Flutamide Trial | 6.1 | diethylstilbestrol 3 mg | flutamide 750 mg | 20 | 20 | | | 40% | 65%
Chang 1996 ECOG Trial (US) | 6.1 | diethylstilbestrol 3 mg | flutamide 750 mg | 48 | 44 | 26.4 | 9.7 | 76% | 44% | 55% | 30% | 20% | 4% | | | | LR | 0.016
Kaisary 1995 Casodex Study Group Trial 0302 (Europe) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28 d | bicalutamide 50 mg | 126 | 119 | 10.3 | 8.1 | 37% | 33% | | | | | 48% | 50% | 1.16 (0.81, 1.67) | Cox PH
Iversen 1994 International Casodex Studies 0306/0307 (stage M1) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28 d | bicalutamide 150 mg | 268 | 573 | 12.8 | 11.0 | 53% | 44% | 28% | 17% | | | | | 1.43 (1.199, 1.707) | Cox PH | 0.0001 | 75% of all pts had failed at last followup
Iversen 1994 International Casodex Studies 0306/0307 (stage M0) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28 d | bicalutamide 150 mg | 160 | 320 | 20.0 27.5 | 39.5 22.3 | | | | | | | 73% | 76% | 0.66 (0.42, 1.04); 1.24 (0.96, 1.61) | Cox PH | 0.074 0.097 | studies 0306 and 0307 report opposite results
Chodak 1995 Casodex study 0303 (US and Canada) | 7.3 | bilateral orchiectomy or goserelin 3.6 mg 28 d | bicalutamide 50 mg | 243 | 243 | 15.5 | 10.8 | 54% | 38% | | | | | 42% | 53% | 1.54 (1.18, 2.0) | Cox PH | 0.002

Evidence Table I.5. Cardiovascular Adverse Events, Monotherapies

| Cardiovascular Nonspecified | | | Peripheral Edema | | | Embolic Events/Phlebitis/Venous Thrombosis | | | Stroke/TIA | | | Angina/MI
| N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies
Orchiectomy | 144 | 0.0 | 1 | 101 | 12.9 | 1 | 101 | 1.0 | 1 | 101 | 2.0 | 1 | 242 | 7.0 | 2
DES | 139 | 26.6 | 3 | 245 | 22.0 | 3 | 463 | 3.3-5.6 | 6 | 270 | 3.7 | 3 | 343 | 3.8 | 4
Cyproterone | 477 | 4.2 | 4 | | | 0 | 84 | 2.4 | 1 | 0 | | 0 | 84 | 3.6 | 1
NSAA | | | 0 | 1127 | 8.6 | 3 | 54 | 0.0 | 2 | 34 | 2.9 | 1 | 34 | 5.9 | 1
LHRH | 873 | 1.3 | 4 | 152 | 18.4 | 2 | 306 | 0.0--1.0 | 3 | 124 | 0.0 | 1 | 259 | 6.9 | 2

Evidence Table I.6. Endocrine Adverse Events, Monotherapies

| Hot Flushes | | | Gynecomastia | | | Impotence
| N Pts | % | N Studies | N Pts | % | N Studies | N Pts | % | N Studies
Orchiectomy | 731 | 50.8 | 7 | 474 | 5.3 | 4 | 339 | 13.3 | 3
DES | 406 | 14.0 | 6 | 285 | 26.7 | 4 | 143 | 16.1 | 2
Choice of Orch/LHRH | 1095 | 43.7 | 5 | 1095 | 2.9 | 5 | 150 | 1.3 | 1
Cyproterone | | | 0 | | | 0 | | | 0
LHRH | 689 | 49.3 | 7 | 339 | 4.4 | 3 | 284 | 20.8 | 2
NSAA | 1786 | 11.3 | 8 | 1766 | 37.7 | 7 | 187 | 5.3 | 2

Evidence Table I.7. Gastrointestinal Adverse Events, Monotherapies

| Gastrointestinal, Nonspecified | | | | Nausea/Vomiting | | | | Diarrhea | | | | GI Pain
| N Pts | % | N Studies | | N Pts | % | N Studies | | N Pts | % | N Studies | | N Pts | % | N Studies
Orchiectomy | 285 | 9.1 | 2 | | 200 | 0.0--1.3 | 2 | | 200 | 0.0 | 2 | | 50 | 2.0 | 1
DES | 42 | 9.5 | 1 | | 227 | 10.6 | 2 | | 42 | 21.4 | 1 | | 0 | | 0
Choice of Orch/LHRH | 0 | | 0 | | 935 | 4.3 | 4 | | 935 | 4.5 | 4 | | 820 | 4.6 | 3
Cyproterone | 0 | | 0 | | | | 0
LHRH | 310 | 9.0 | 2 | | 328 | 4.6 | 3 | | 106 | 6.6 | 1 | | 0 | | 0
NSAA | 34 | 11.8 | 1 | | 1418 | 9.2--9.3 | 5 | | 1452 | 5.4 | 6 | | 1461 | 7.0 | 4

Evidence Table I.8. Adverse Events Leading to Withdrawal from Therapy, Pooled Results, Monotherapies

Treatment (tx) | Studies | tx | tx | tx
DES 1 | 1 | 98 | 14 | 14.3%
DES 3 | 5 | 284 | 53 | 18.7%
leupr 1 daily | 1 | 268 | 0 | 0.0%
goser 3.6 1 mo | 11 | 1679 | 33 | 2.0%
goser 10.8 3 mo | 2 | 77 | 1 | 1.3%
buser 0.4 | 1 | 72 | 3 | 4.2%
fluta 750 | 2 | 92 | 9 | 9.8%
bica 50 | 3 | 628 | 25 | 4.0%
nilut 300 | 1 | 44 | 3 | 6.8%
cypr 250 | 1 | 82 | 1 | 1.2%
cypr 300 | 2 | 405 | 17 | 4.2%

Table I.9. Adverse Events Leading to Withdrawal from Therapy, Monotherapies, Randomized Trials

Comp Code | Study | Stage | cx | tx | N cx | N Wdl cx | % Wdl cx | comment cx | N tx | N Wdl tx | % Wdl tx | comment tx
1.0 | Robinson | D | orch | DES 1 | 101 | 4 | 4.0% | non-CV | 98 | 14 | 14.3% | 13 CV, 1 other
2.2 | Vogelzang | D2 | orch | goser 3.6 1 mo | 145 | 0 | 0.0% | | 138 | 1 | 0.7%
2.2 | Kaisary '91 | D2 | orch | goser 3.6 1 mo | 144 | | 0.0% | | 148 | 0 | 0.0%
2.3 | Bruun | D2 | orch | buser 0.4 | 46 | 0 | 0.0% | | 72 | 3 | 4.2%
3.2 | Waymont | C+D | DES 3 | goser 3.6 1 mo | 126 | 36 | 28.6% | | 124 | 2 | 1.6%
3.2 | Citrin | D2 | DES 3 | goser 3.6 1 mo | 19 | 3 | 15.8% | 3 CV | 48 | 0 | 0.0%
3.2 | Moffat | C+D | DES 3 | goser 3.6 1 mo | 33 | 6 | 18.2% | | 109 | 9 | 8.3%
6.4 | Pavone-Macaluso | C+D | DES 3 | cypr 250 | 73 | 2 | 2.7% | 1 CV, 1 GYN | 82 | 1 | 1.2% | 1 NEU
6.4 | Moffat | C+D | DES 3 | cypr 300 | 33 | 6 | 18.2% | | 230 | 6 | 2.6%
7.3 | Kaisary '95 | D | orch/goser 3.6 1mo | bica 50 | 125 | 1 | 0.8% | HF | 118 | 2 | 1.7% | 1 GYN, 1 PN
7.3 | Chodak | D2 | orch/goser 3.6 1mo | bica 50 | 243 | 4 | 1.6% | | 243 | 2 | 0.8%
8.1 | Thorpe | D | cypr 300 | goser 3.6 1 mo | 175 | 11 | 6.3% | 4 CV, 1 GI, 6 other | 175 | 7 | 4.0% | 2 CV, 5 other

Evidence Table I.10. Adverse Events Leading to Withdrawal from Therapy, Phase II Studies

Study | Stage | tx | N | N Wdl | % Wdl | comment
Fernandez | C+D | goser 10.8 3 mo | 77 | 1 | 1.3%
1996
Dijkman | C+D | goser 3.6 1 mo | 190 | 0 | 0.0%
1995 | | goser 10.8 3 mo
Metz 1988 | C+D | goser 250 daily | 129 | 0 | 0.0%
| | goser 3.6 1 mo
Kienle 1996 | advanced | leupr 3.75 1 mo | 205 | 7 | 3.4%
| | mono/+antiandrogen
Bischoff | B-D | leupr 3.75 1 mo | 190 | 4 | 2.1%
1990 | | leupro 7.5 1 mo/daily
Oosterlinck | C+D | fluta 750 | 75 | 5 | 6.7% | 3 HE, 1 GI, 1 GYN
1996 | C+D | orch/LHRHa+fluta 750 | 830 | 39 | 4.7% | 27 GI, 4 HE, 4 HF, 4
| | | | | | other
Akaza 1993 | C+D | fluta 375 | 52 | 1 | 1.9% | HE
McFarlane | D2 | fluta 750 | 17 | 4 | 23.5% | 2 DE, 2 GI
1983 | progressed
Decensi 1991 | D | nilut 300 | 44 | 3 | 6.8% | GI
Lunglmayr | C+D | bica 50 | 267 | 21 | 7.9%
1995

Evidence Table I.11. Adverse Events by Degree of Severity, Monotherapies

| Study | Group | N | None | Mild | Mod | Sev | L-T | Leth | ?
Cardiovascular System | de Voogt ^a^ | DES 3 | 73 | 65.8% | 26.0% | | 5.5% | | 2.7%
| de Voogt ^a^ | cypr 250 | 84 | 90.5% | 4.8% | | 1.2% | | 3.6%
Bradycardia | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0% | 2.4% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
Chest pain | Chang ^b^ | DES 3 | 42 | | 0.0% | 2.4% | 2.4% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 2.9% | 2.9% | 0.0% | 0.0% | 0.0%
Myocardial infarction | Chang ^b^ | DES 3 | 42 | | 0.0% | 2.4% | 0.0% | 0.0% | 4.8%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
Stroke | Chang ^b^ | DES 3 | 42 | | 2.4% | 2.4% | 0.0% | 2.4% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 2.9%
Cerebrovascular accident | Chang ^b^ | DES 3 | 42 | | 0.0% | 2.4% | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
Transient ischemic attack | Chang ^b^ | DES 3 | 42 | | 4.8% | 0.0% | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
High blood pressure | Huben ^c^ | orch/DES 3 | 54 | 83.3% | 11.1% | | 0.0% | | | 5.6%
| Huben ^c^ | buser .2/.4 | 106 | 76.4% | 14.2% | | 0.0% | | | 9.4%
| Chang ^b^ | DES 3 | 42 | | 16.7% | 9.5% | 7.1% | 11.9% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 17.6% | 8.8% | 5.9% | 5.9% | 0.0%
Murmur | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 2.9% | 0.0% | 0.0% | 0.0% | 0.0%
Peripheral edema | Huben ^c^ | orch/DES 3 | 54 | 57.4% | 35.2% | | 1.9% | | | 5.6%
| Huben ^c^ | buser .2/.4 | 106 | 70.8% | 18.9% | | 0.9% | | | 9.4%
| Chang ^b^ | DES 3 | 42 | | 11.9% | 16.7% | 0.0% | 2.4% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
Phlebitis/thrombosis | Chang ^b^ | DES 3 | 42 | | 2.4% | 4.8% | 2.4% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0% | 0.0% | 0.0%
CV complications | Chang ^b^ | DES 3 | 42 | | 2.4% | 0.0% | 2.4% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 2.9% | 0.0% | 0.0% | 0.0% | 0.0%
Gastrointestinal System | Chang ^b^ | DES 3 | 42 | | 4.8% | 2.4% | 2.4%
| Chang ^b^ | fluta 750 | 34 | | 8.8% | 2.9% | 0.0%
Anorexia | Huben ^c^ | orch/DES 3 | 54 | 75.9% | 16.7% | | 1.9% | | | 5.6%
| Huben ^c^ | buser .2/.4 | 106 | 72.6% | 16.0% | | 1.9% | | | 9.4%
Nausea/vomiting | Huben ^c^ | orch/DES 3 | 54 | 81.5% | 13.0% | | 0.0% | | | 5.6%
| Huben ^c^ | buser .2/.4 | 106 | 82.1% | 7.5% | | 0.9% | | | 9.4%
Vomiting | Chang ^b^ | DES 3 | 42 | | 11.9% | 4.8% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 14.7% | 2.9% | 0.0%
Diarrhea | Huben ^c^ | orch/DES 3 | 54 | 85.2% | 9.3% | | 0.0% | | | 5.6%
| Huben ^c^ | buser .2/.4 | 106 | 84.0% | 6.6% | | 0.0% | | | 9.4%
| Chang ^b^ | DES 3 | 42 | | 16.7% | 4.8% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 11.8% | 0.0% | 0.0%
Endocrine System
Gynecomastia | Chang ^b^ | DES 3 | 42 | | 35.7% | 38.1% | | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 29.4% | 50.0% | 0.0%
Hot flushes | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 5.9% | 0.0% | 0.0%
Sexual function change | Chang ^b^ | DES 3 | 42 | | 9.5% | 19.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 5.9% | 17.6% | 0.0%
Central/Peripheral Nervous System
Neurologic | Chang ^b^ | DES 3 | 42 | | 11.9% | 2.4% | 2.4%
| Chang ^b^ | fluta 750 | 34 | | 11.8% | 8.8% | 2.9%
Hemic/Lymphatic System
Hematologic | Chang ^b^ | DES 3 | 42 | | 14.3% | 2.4% | 7.1%
| Chang ^b^ | fluta 750 | 34 | | 29.4% | 8.8% | 8.8%
Hemorrhage | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 2.9% | 0.0% | 0.0%
Respiratory System | Chang ^b^ | DES 3 | 42 | | 7.1% | 4.8% | 4.8%
| Chang ^b^ | fluta 750 | 34 | | 5.9% | 0.0% | 0.0%
Skin/Appendages
Hair loss | Chang ^b^ | DES 3 | 42 | | 2.4% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0%
Urogenital System | Chang ^b^ | DES 3 | 42 | | 42.9% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 41.2% | 8.8% | 0.0%
Metabolic/Hepatic/ Nutritional
Hepatic | Chang ^b^ | DES 3 | 42 | | 11.9% | 4.8% | 2.4%
| Chang ^b^ | fluta 750 | 34 | | 14.7% | 17.6% | 8.8%
Jaundice | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 2.9% | 0.0%
Hyperglycemia | Chang ^b^ | DES 3 | 42 | | 0.0% | 4.8% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 0.0%
Miscellaneous
Fever | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 2.9% | 0.0%
Night sweats | Chang ^b^ | DES 3 | 42 | | 2.4% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 2.9% | 0.0% | 0.0%
Dehydration | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 2.9%
Infection | Chang ^b^ | DES 3 | 42 | | 2.4% | 19.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 5.9% | 8.8% | 2.9%
Mucositis | Chang ^b^ | DES 3 | 42 | | 11.9% | 0.0% | 2.4%
| Chang ^b^ | fluta 750 | 34 | | 5.9% | 0.0% | 0.0%
Dehydration | Chang ^b^ | DES 3 | 42 | | 0.0% | 0.0% | 0.0%
| Chang ^b^ | fluta 750 | 34 | | 0.0% | 0.0% | 2.9%

a de Voogt, Klijn, Studer et al., 1995

b Chang, Yeap, Davis et al., 1996

c Huben and Murphy, 1988

Table I.12. Adverse Events Reported in Package Inserts

Agent(s)/Dosage Form | DES | Orch | Orch | Orch | Leupr | Leupr | Leupr | Leupr | Goser | Goser | LHRH | LHRH | LHRH | Orch | Leupr | Leupr | LHRH
Total N | 101% | 24% | 254% | 232% | daily 98% | 1 mo 56% | 3 mo 94% | 4 mo 49% | 1 mo 242% | 3 mo 157% | a +Fluta 285% | a +Fluta 294% | a +Fluta 407% | +Nilut 225% | +Plac 202% | +Nilut 209% | a +Bica 401%
Cardiovascular System
CHF | 5.0% | | 1.2% | | 1.0% | | | | 5.0%
ECG changes/ischemia | 21.8% | | | | 19.4%
chest pain | | | | | | | | | | | | | 4.9% | | 4.5% | 7.2% | 6.0%
high blood pressure | 5.0% | | | 2.6% | 8.2% | | | | | | | | 4.4% | 5.3% | 9.9% | 9.1% | 5.2%
peripheral edema | 29.7% | | | | 12.2% | | | | | | | | 6.9% | | 17.3% | 12.4% | 8.5%
edema | | 20.8% | 7.9% | | | 12.5% | | 8.2% | 7.0%
phlebitis/thrombosis | 9.9% | | | | 2.0%
Gastrointestinal System | | 12.5% | | | | 26.8% | | 10.2%
anorexia | 5.0% | | 2.0% | | 6.1% | | | | 5.0% | | | | | | 6.4% | 11.0%
constipation | 8.9% | | | 3.9% | 7.1% | | | | | | | | 12.3% | 7.1% | 16.8% | 19.6% | 16.7%
nausea | | | 2.0% | 6.0% | | | | | 5.0% | | | | 11.1% | 9.8% | 8.4% | 26.8% | 11.0%
nausea/vomiting | 16.8% | | | | 5.1% | 5.4% | | | | | 10.2% | 10.9%
vomiting | | | | | | | | | | | | | 4.9% | | 4.0% | 5.7% | 3.0%
diarrhea | | | | | | | | | | | 3.9% | 11.9% | 24.1% | | | | 10.0%
abdominal pain | | | | | | | | | | | | | 7.6% | | | 10.0% | 8.2%
Endocrine System
gynecomastia | | | | | | | | | | 8.3% | 10.9% | 8.8% | 5.7% | | 11.9% | 10.5% | 4.7%
gynecom/breast pain/tenderness | 62.4% | | | | 7.1% | 58.9%
hot flushes | 11.9% | 8.3% | 53.1% | 22.4% | 56.1% | 5.4% | 58.5% | 46.9% | 62.0% | 63.7% | 56.8% | 60.9% | 49.6% | 28.4% | 59.4% | 66.5% | 48.9%
impotence | 11.9% | | 16.1% | | 4.1% | | | | 18.2% | | 29.1% | 33.0% | 7.1% | | 12.9% | 11.0% | 5.0%
loss of libido | | | 15.0% | | | | | | 21.1% | | 30.9% | 36.1% | | | 4.5% | 11.0%
Hepatic
increased AST | | | | 3.9% | | | | | | | | | | 8.0% | 13.9% | 12.9%
increased ALT | | | | 4.3% | | | | | | | | | | 7.6% | 8.9% | 9.1%
increased AST/ALT | | | | | | | | | | | | | 9.8% | | | | 7.2%
Special Senses
impaired adaptation to dark | | | | 1.3% | | | | | | | | | | 12.9% | 5.4% | 56.9%
impaired adaptation to light | | | | | | | | | | | | | | | 1.0% | 7.7%
chromotopsia | | | | | | | | | | | | | | | 0.0% | 8.6%
abnormal vision | | | | 1.7% | | | | | | | | | | 6.7% | 4.5% | 6.2%

Evidence Table I.13. Analysis Data Set for 2-Year Hazard Rates for Prostate Cancer Patientsa

Study # | Ln-Hazard | variance | orch | DES | leup | goser | buser | flut | bicalut | cypro | LHRH | NSAAs
98 | -.3955 | .0147 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
98 | -.5144 | .0155 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
800 | -.7721 | .0189 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
800 | -.6394 | .0181 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
686 | .0690 | .0364 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
686 | .2571 | .0220 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0
535 | -.8068 | .0285 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
535 | -.7046 | .0278 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0
97 | -.5760 | .0189 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
97 | -.5760 | .0187 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
663 | -.9528 | .1665 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
663 | -.7721 | .0573 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
188 | -1.3925 | .0831 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
188 | -1.1012 | .0340 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0
444 | -1.3418 | .0164 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
444 | -1.1561 | .0141 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
279 | -.3093 | .0183 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
279 | -.5134 | .0214 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
687 | -.5760 | .0126 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
687 | -.1670 | .0100 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
401 | -1.5572 | .1101 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
401 | -.8782 | .0678 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1
477 (C+D) | -.8068 | .0448 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
477 (C+D) | -.8422 | .0387 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1
797 | .6375 | .0061 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
797 | .5576 | .0060 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
290 | -.6394 | .0059 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
290 | -.4543 | .0026 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
280 | -.4842 | .0150 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 0
280 | -.4248 | .0140 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
439 | -.4543 | .0186 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
439 | -.4248 | .0194 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0
755 | -.6173 | .0878 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
755 | -.1211 | .0864 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1
477 (D2) | -.6075 | .0740 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
477 (D2) | -.3093 | .0457 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1
1482 | -1.5572 | .0330 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
1482 | -2.0570 | .0261 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0
839 | -.5760 | .0118 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
839 | -.6934 | .0118 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

a Three studies were omitted because they either did not provide the necessary survival data ( Koutsilieris and Tolis, 1985; Boccon-Gibod, Fournier, Bottet et al., 1997) or they reported no mortality in one arm and as a result it was impossible to calculate a hazard ratio for that study ( Lund and Rasmussen, 1988).

orch: orchiectomy; DES: diethylstilbestrol; leup: leuprolide; goser: goserelin; buser: buserelin; flut: flutamide; bicalut: bicalutamide; cypro: cyproterone; LHRH: luteinizing hormone-releasing hormone; NSAAs: nonsteroidal antiandrogens

(Key to study numbers on next page)

Key to Study Numbers for Evidence Table I.13

Study # | Reference
98 | Kaisary, Tyrrell, Peeling et al., 1991
800 | Vogelzang, Chodak, Soloway et al., 1995
686 | Bruun and Frimodt-Moller 1996
535 | The Leuprolide Study Group 1984
97 | Waymont, Lynch, Dunn et al., 1992
663 | Citrin, Resnick, Guinan et al., 1991
188 | Huben and Murphy, 1988
444 | Veterans Administration Cooperative Urological Research Group, 1967
279 | Robinson, Smith, Richards et al., 1995
687 | Iversen, Tveter, and Varenhorst 1996
401 | Chang, Yeap, Davis et al., 1996
477 (C+D) | Pavone-Macaluso, de Voogt, Viggiano et al., 1986
797 | Chodak, Sharifi, Kasimis et al., 1995
290 | Iversen, 1994
280 | Kaisary, Tyrrell, Beacock et al., 1995
439 | de Voogt, Klijn, Studer et al., 1990
755 | Ostri, Bonnesen, Nilsson et al., 1991
477 (D2) | Pavone-Macaluso, de Voogt, Viggiano et al., 1986
1482 | Iversen, Tyrrell, Kaisary et al., 1998
839 | Blackard, Byar, and Jordan, 1973