# Management of Newly Diagnosed Patients with Epilepsy: A Systematic Review of the LiteratureAdditional Appendixes

## Appendix 1. Criteria for Referral of Patients with EpilepsyReport on Phase One

Prepared by: Susan D. Ross, MD, FRCPC Principal Investigator Isabella Sledge, MD Jacqueline French, MD Rhonda Estok, RN Sameer Chopra, MA Investigators

### Background

In February 1999, the Agency for Health Care Policy and Research (AHCPR) awarded a task order contract to MetaWorks to develop an evidence report on "Criteria for Referral of Patients with Epilepsy." The topic was nominated by the Centers for Disease Control and Prevention (CDC) for the purpose of developing a framework for organizing and optimizing the care of persons with epilepsy. The CDC's request for an evidence report on this topic followed from their September 1997 conference entitled "Living Well With Epilepsy." The participants divided into work groups which generated several recommendations. Among these was the development of a testable framework for effective care of persons with epilepsy. The CDC determined that this framework was to be the result of a preliminary literature search examining models of care in epilepsy and other chronic conditions and a stakeholders meeting with representatives from various constituencies involved in improving epilepsy care. A systematic literature review based on the framework would then be undertaken to draft an evidence report. This evidence report could then be used by providers, professional societies and payors as a basis for decision-making about effective care for patients with epilepsy.

The development of this evidence report is being carried out in two phases. The first phase was preparatory to a meeting of representatives from the AHCPR, the CDC, and stakeholders from various constituencies involved in improving the care of patients with epilepsy. The purpose of this meeting was to define questions to guide a more comprehensive literature review to generate an evidence report on effective referral criteria for persons with epilepsy. The subsequent literature review and synthesis will constitute the second phase of the project.

This report summarizes phase I tasks and findings: the preliminary literature review and the stakeholders' meeting as well as the recommendation regarding direction for future work.

### Literature Review

A preliminary literature review was conducted for models of care in epilepsy and other chronic diseases. We were particularly interested in care management issues that are associated with disease conditions of low prevalence and high chronicity. We were interested in population- and policy-level information as opposed to clinical patient-level information. The sources listed in Appendix A were searched for information relative to referral criteria, guidelines for referring categories of patients needing more specialized care, and studies assessing the impact of specialty care on patient outcomes.

The information sources searched and the yields for each are summarized in Appendix A. The results of the preliminary literature search are described below.

#### Models of Care in Other Chronic Diseases

A review of the literature in other disease settings uncovered information of interest to the study of epilepsy. Some algorithms and models designed for the care of patients with asthma and diabetes, for example, have aspects that are applicable to the development of care pathways for epilepsy. Outcome studies in the area of childhood cancers also are of interest.

##### Asthma

Many guidelines and treatment algorithms for managing asthma follow a stepped-care approach: as patients' symptoms get more severe, their care is stepped up to include more intensive interventions. Each step in the level of care is associated with a set of signs and symptoms and has prescribed interventions assigned. These management pathways do not dictate the level at which patients require referral; it is up to the individual clinician to determine when the level of care required exceeds his or her capabilities and to refer accordingly. One example of such a guideline for asthma management is a pathway developed by the Institute for Clinical Systems Integration.^1^

##### Diabetes

There are two information sources of interest in the area of diabetes care. The first is a guideline for specialty referral for patients with diabetes developed by the Diabetes Treatment Centers of America.^2^ This guideline outlines triggers for specialty referral in the care of diabetic patients. Specific symptoms, physical exam findings, and test results indicating the need for specialty care are detailed. This guideline is intended for use by primary care physicians.

The second applicable source is a paper by Roman and Harris from 1997 describing four models of care for patients with diabetes.^3^ The intensive care model is specialty-based with the endocrinologist/diabetes team providing the primary care. Evidence from the Diabetes Care and Complications Trial (DCCT) supports the use of this model for type I diabetics.^4^ The DCCT study showed that intensive blood sugar control decreased complications by 50 to 70% in these patients. Only 10% of diabetic patients have type I diabetes, and extending this level of care for all diabetic patients is neither feasible nor appropriate. Other categories of patients must follow the comanagement model, where the primary care physician provides the majority of care with periodic visits made to the specialist, or the expert system where the generalist is assisted by algorithms which provide guidance on the care, education and referral of patients. The fourth model is the mini-clinic approach that is popular in Britain. In this model, practice time is carved out and diabetic patients are seen at set intervals. Teaching and specialty referral resources are available to the patient at the time of the visit. This paper suggests that patients can be stratified by clinical characteristics and risk factors and assigned different intensities of care as appropriate.

##### Childhood Cancer/Serious Blood Disorders

There is evidence to support that caring for patients diagnosed with sickle cell disease or Wilms' tumor in pediatric specialty centers decreases morbidity and mortality and overall costs.^5,6^ Thus, improved outcomes and decreased costs are associated with increased specialty care for these disorders.

##### Disease Management Approach

In determining optimal care pathways for epilepsy some attention must be paid to reimbursement issues. An approach that emphasizes early specialty care and referral for certain categories of patients may not be possible in certain managed care settings. Some managed care organizations are developing disease management models whereby resources are allocated for the disease as a whole, rather than distributed over the course of the disease as services are rendered. Thus, the most efficient care pathways will be pursued. If early referral for certain categories of patients is shown to be effective, then perhaps barriers to such referral can be reduced or eliminated. This disease management approach is being tested for many chronic diseases, but little data is yet available.^7,8^

#### Models of Care in Epilepsy

The majority of the work on models of care for epilepsy comes from Europe. There are two studies relating specialty referral to outcomes. There are also some models of integrated care for patients with epilepsy.

##### Europe

A review of epilepsy care in the Netherlands stated that all patients with epilepsy are referred to a neurologist.^9^ Additionally, there are three specialized centers with intensive services. Extended mobile outpatient clinics bring specialists and diagnostic/monitoring equipment to the community. Admissions to epilepsy centers have been reduced in the areas covered by the mobile clinics.

In Italy, 14 epilepsy centers followed over 3,000 patients for more than 2 years and found the percent of patients in complete remission increased from 13% prior to evaluation in a specialty center, to 28% after the evaluation.^10^

Work from England outlining the care needs of epilepsy patients offers a flow diagram for referral pathways.^11^ It is interesting to note that all referral paths have a loop that feeds back care to the generalist after subspecialty referral. In England, epilepsy care is organized geographically by district with specialized epilepsy nurses serving as liaisons between hospital-based specialist care and local physicians. Guidelines are developed and distributed regionally.^12^

In Scotland, the Scottish Intercollegiate Guidelines Network published a management guideline for epilepsy.^13^ Section 8 of the document deals with criteria for referral of patients. The guideline assigns tasks at different timepoints (initial diagnosis, monitoring, etc.) to primary care or specialty care providers. There is a clear delineation between primary and secondary spheres of care.

##### United States

In the United States, the National Association of Epilepsy Centers (NAEC) compiled a document detailing the level of services expected at tertiary and fourth-level epilepsy centers.^14^ The document also describes criteria for referral and provides a flow diagram. According to the NAEC, patients should be referred from generalists to specialists if seizure control has not been achieved within three months. A referral to an epileptologist should follow if there is still no control in another nine months. Referral to an epilepsy center should be based on need for invasive diagnostic tests, inpatient psychiatric evaluation, difficult pharmacologic challenges, possible psychogenic seizures, or evaluation for surgery.

#### Summary of Literature Review

In summary, models of care in other disease settings suggest that patients can be stratified according to clinical characteristics and risk factors. Different intensities of services may be appropriate for different categories of patients. For certain patients, outcomes may be improved when specialized care is introduced early on. Emphasizing a disease management approach is key to arriving at the most effective care pathway. Models of care in epilepsy have primarily been established in other countries. To date, no models of care for epilepsy have stratified patients into clinical categories that indicate the need for certain levels of care.

### Summary of Stakeholders' Meeting

A meeting of stakeholders representing various constituencies in the field of epilepsy was held on March 25, 1999, in Philadelphia, Pennsylvania. The purpose of the meeting was to develop a testable framework that could be supported with evidence from the literature for organizing the care of persons with epilepsy. Present at the meeting were representatives from AHCPR, CDC, MetaWorks, and stakeholders from the following constituencies: epileptology, neurology, primary care, nursing, managed care, healthcare purchasing, as well as patient representatives. A list of attendees is attached in Appendix B. The agenda for the meeting (Appendix C) comprised a presentation of the project background, the results of the literature search (described above), and an overview of the Lovelace Health System's approach to provider education and outcomes research in epilepsy. After the presentations, attendees were divided into constituency groups to generate a summary of their experience with referral patterns for epilepsy in the real world, and how referrals might occur in an ideal world. Enclosure B, "Real" and "Ideal" Experiences With Referrals for Epilepsy Management (Appendix D) was employed as a starting point for organizing these discussions. A spokesperson from each constituency then presented a summary of their discussion to the group. Participants discussed several different referral strategies that emerged as a result of the literature review and discussion of stakeholders' experience and merged these strategies into a framework to guide future study.

A summary of key points emerging from the meeting is described below. Detailed meeting minutes are contained in Appendix E.

#### Project Background/Preliminary Literature Review

Already described in detail above.

#### Lovelace Health System Seizure Disorder Program Overview

Margaret Gunter, PhD, presented Lovelace Health System's disease management approach to improving the quality of care for epilepsy patients. Guidelines were developed which combined evidence-based principles with expert consensus. Existing guidelines include pediatric, adult, and emergency epilepsy care (including status epilepticus). Guidelines include suggestions for criteria to be used for determining referral. The guidelines were piloted and modified before being introduced to clinicians through intensive education efforts. An assessment of the effectiveness of these guidelines is ongoing by monitoring key outcome measures such as quality of life, patient and physician satisfaction, and utilization/cost measures. Data on these outcome measures are not yet available.

A discussion point that emerged from the presentation was whether, given the relatively low prevalence of epilepsy in a general practice panel, it is efficient (and cost effective) to train generalists to work-up, treat and monitor epilepsy patients or whether it would be more efficient to have specialists diagnose and manage all aspects of patient care.

#### Discussion Of Stakeholders' Experiences In The 'Real' And 'Ideal' Worlds

##### Primary care

All of the reasons apply for referral to specialized care listed in the 'real world' column of Enclosure B. In the ideal world, each referral decision is situation-specific and is heavily influenced by provider knowledge and comfort level. In the ideal world, patient preference would take precedence over reimbursement issues. It was felt that education about epilepsy management is important for providers even if only to increase provider comfort in responding to seizures and to improve triage in urgent care situations. The concept of patient-centered practice policies was introduced whereby care decisions are based on the needs of the patient rather than on a pre-defined role of particular providers.

##### Neurology

The diagnosis and ongoing treatment of epilepsy was plotted as a timeline and six critical timepoints were identified when expert intervention might be necessary. These six timepoints are: (1) initial diagnosis -- expert knowledge may be needed to reduce misinterpretation of EEGs, to accurately rule out other diagnoses such as syncope and pseudoseizure, and to obtain appropriate imaging studies; (2) choice of initial medication; (3) the need for supplements such as folate or calcium and the possibility of drug interactions; (4) initial monitoring- how often and what types of monitoring are required; (5) ongoing monitoring/treatment- dealing with comorbidity, counseling on issues such as pregnancy, employment, genetic testing, and driving; (6) cessation of medication.

Different populations of patients are perceived as being more difficult to treat than others. Young patients (under age 18) with generalized seizures are felt to be easier to manage, whereas those with focal seizures are a bit more challenging. Older patients, patients with brain lesions, or who are passive or difficult to counsel are felt to pose an even greater challenge. The group discussed the fact that 'easier' patients may not require referral, but that a breakdown at any of the six timepoints should trigger referral.

##### Epileptology

Patients are referred from all different timepoints in the course of their care. In the real world, reimbursement often dictates which patients are referred. Even when referred from high quality, appropriate neurological care, patients still get 'value-added' services at epilepsy centers. The cost of the visit to see an epileptologist is often the same as for a general neurologist, but other services such as intensive counseling are available through the epileptologist. Often patients are able to spend more time in consultation with the epileptologist because the specialist at a center will see fewer patients per hour than will a typical neurologist. Epileptologists refer patients back to generalists in order to maintain a collegial relationship and to encourage future referrals. Often, however, patients do not want to return to a generalist for care. Once an evaluation and care plan is in place, patients should return to general care and have subsequent referrals if problems arise. Empowering patients will be important in modifying patterns of care.

The desire for all patients to be 'seizure-free with no side effects' often drives referrals. Decisions about invasive medical interventions must take into account the patients' quality of life. Seizures should be controlled to the patient's rather than the physician's satisfaction. Possibly 30% of all epilepsy patients cannot achieve this seizure-free goal.

##### Health Services/Payors

Employers select providers and health plans with almost no information. Cost effectiveness data is critical. The only way changes in established referral patterns will occur is if they are seen as cost-saving. Health plans are often selected by patients on the basis of relationships with certain providers. In well-organized systems, curbside consultations can work and save costs.

##### Consumers

Patient preference is and should be the driver of referrals. Patient education fuels demand for appropriate care. One common reason patients give for requesting referral is the desire for advanced therapy. There is concern that if specialists become the gatekeepers, patients with multiple conditions may not receive the appropriate comprehensive care they need if they use the specialist as their primary physician. Patients may not seek care initially because of the stigma of epilepsy. Physicians often overreact to seizures. Education of primary care givers as well as patients is of utmost importance. The patient's goals need to be identified, but only after the patient has received adequate information about the disease and about the available treatment options. The goal of 'no seizures, no side effects' is an appropriate goal for many, and this goal should be articulated as part of a public education campaign.

#### Approaches To A Framework/Model For Referral Criteria

Four ways of addressing patterns of referral were proposed:

1. Point of care -- expert opinion may be required at certain important timepoints in the delivery of care such as at the first diagnosis, initial choice of medication, etc.
2. Time-based -- referrals if remission/control of seizures not obtained within a certain period of time.
3. Population-based -- particular at-risk populations may require referral.
4. Service-oriented approach -- what facilities/services/resources are needed to manage epilepsy and where are they located?

After much discussion about whether any of these models might generate researchable questions, it was decided that models 3 and 4 were complementary and possibly researchable. A matrix of potentially important services for the management of epilepsy for various patient populations is draftable. Areas where there are no data may be identified; other areas may be supported by existing data. This approach avoids assigning specific providers to certain levels of care. One caveat to consider before embarking on this search for evidence to support the framework is that outcomes data will likely be missing. Another caveat is that patients studied in the literature may not be representative of the epilepsy population as a whole. It may be difficult to apply population-based guidelines using evidence gathered from a skewed population of patients.

#### Populations Requiring Referral

A list of 9 potential populations requiring referral was generated. A consensus vote was taken to identify the 5 populations with the highest research priority. These are as follows:

1. All patients undergoing first diagnosis
2. Patients demonstrating intractability
3. Patients with comorbidities
4. Patients with side effects from medications
5. Patients considering withdrawal from medication.

Four other populations with lower priority were also identified: women, the elderly, patients presenting with febrile seizures, and patients experiencing drug interactions.

The stakeholders then identified general categories of services for possible research for each of the populations. Time, however, did not allow for completion of this undertaking. It was decided that team members from MetaWorks would expand on this work and generate a framework grid to be used in identifying potential researchable questions for different patient populations requiring referral.

### Direction For Further Study

A framework grid was developed outlining specific resources required at each point of care (diagnosis, treatment and monitoring) for each of the five highest-priority patient populations highlighted by the stakeholders (see Appendix F). This framework was created to aid in the retrieval, organization and synthesis of best available evidence for the management and referral of patients with epilepsy. The five priority populations are listed on the Y-axis. The X-axis lists healthcare services and all other resources that might be considered necessary for optimum care during the diagnosis, treatment and monitoring of epilepsy patients. Each white cell represents a particular area of inquiry that may be further researchable using the published literature. The darkened cells represent healthcare services or resources deemed by MetaWorks and University of Pennsylvania co-investigators as not applicable for the particular population on the Y-axis.

Using the matrix framework, researchers can assess the quantity and quality of available evidence examining the clinical outcomes resulting from the application of a particular service to a particular patient population at certain time points of care. Providers, professional societies and payors can use the evidence to guide decisions about referrals and resource utilization. The purpose of this exercise is to improve outcomes for these populations through the application of best evidence to clinical practice and management of epilepsy.

This targeted literature review and synthesis of evidence will constitute phase II of this project.

### References

1 Diagnosis and Management of Asthma in Adults. Institute for Clinical Systems Integration (ICSI). May 1998.
2 Specialty Referral Guidelines for People With Diabetes. Diabetes Treatment Centers of America (DTCA). 1998. [pmcid: 325579].
3 Roman S. H., and Harris M.I. Management of Diabetes Mellitus from a Public Health Perspective. Current Therapies for Diabetes. 1997;26:443-474.
4 Position Statement: Implications of the Diabetes Control and Complications Trial. Diabetes. 1993;42.
5 Yang Y., Shah A. K., Watson M., and Mankad, V.N. Comparison of Costs to the Health Sector of Comprehensive and Episodic Health Care for Sickle Cell Disease Patients. Public Health Reports. 1995;110:80-85. [pmid: 7838948].
6 Pritchard J., Stiller C. A., and Lennox E.L Overtreatment of Children With Wilms' Tumor Outside Pediatric Oncology Centers British Medical Journal 1989 299(6703): 835 836 2555000
7 Piro L., and Doctor J. Managed Oncology Care: The Disease Management Model. Cancer (Supplement). 1998;82:2068-2075.
8 Bernard D. B., Townsend R.R., and Sylvestri M.F. Health and Disease Management: What is it and Where is it Going? What is the Role of Health and Disease Management in Hypertension?. American Journal of Hypertension. 1998;11:103S-108S.
9 De Boer H. M, Aldenkamp A. P., and Overweg J. Epilepsy Care in the Netherlands. Acta Neurologica Scandinavia (Supplement). 1992;140:101-105.
10 Osservatorio Regionale per l'Epilessia (OREp), Lombardy. Epilepsia. 1997;38:1338-43. [pmid: 9578530].
11 Brown S., Betts T., Chadwick D., Hall B., Shorvon S., and Wallace S. An Epilepsy Needs Document. Seizure. 1993;2:91-103. [pmid: 8167971].
12 Taylor M.P., Readman S., Hague B., Boulter V., Hughes L., and Howell S. A District Epilepsy Service, With Community-Based Specialist Liaison Nurses and Guidelines for Shared Care. Seizure. 1994;3:121-127. [pmid: 8081638].
13 Scottish Intercollegiate Guidelines Network (SIGN). 1997.
14 Epilepsia (Supplement). 1990;31:S1-S2.

### Attachment A: Information Sources, Search Terms, Yield, and Papers Retrieved for Review

#### Preliminary Evidence Review

Conducted in Preparation for Stakeholder's Meeting and Preparation of Draft Framework

1. MEDLINE (via telnet using MeSH headings)
  - MeSH terms epilepsy and diagnosis yielded 4420 abstracts. Abstract review yielded 19 potentially relevant abstracts (full-text papers retrieved). Remainder sorted by category:
    a. 1236 abstracts on diagnosis;
    b. 323 abstracts on treatment/management;
    c. 227 abstracts on monitoring/patient outcomes;
    d. 87 abstracts on incidence/prevalence;
    e. 2547 rejected abstracts.
  - MeSH terms epilepsy and practice guidelines yielded 37 abstracts f) 9 relevant papers retrieved and reviewed (full-text).
  - String searches on the words model (or models) of care; MeSH terms organizational models and outcome assessment
  - Yield: 12 full-text papers retrieved (7 epilepsy specific, 5 alternate models of care).
2. PubMed (National Library of Medicine, www.nlm.nih.gov) Search One PubMed Search Terms: "epilepsy and referral" MEDLINE Translation: ("epilepsy"[MeSH Terms] OR epilepsy[Text Word]) AND ("referral and consultation"[MeSH Terms] OR referral[Text Word])) Yield: 224 citations screened for relevant titles Search Two PubMed Search Terms: "epilepsy and dignosis and management and practice guidelines and human" MEDLINE Translation: ((((("epilepsy"[MeSH Terms] OR epilepsy[Text Word]) AND (((("diagnosis"[Subheading] OR "prognosis"[MeSH Terms]) OR "physical examination"[MeSH Terms]) OR "diagnosis"[MeSH Terms]) OR diagnosis[Text Word])) AND management[All Fields]) AND ("practice guidelines"[MeSH Terms] OR practice guidelines[Text Word])) AND ("human"[MeSH Terms] OR human[Text Word])) Yield: 6 citations screened for relevant titles Search Three Pub Med Search Terms: "seizures and diagnois" Medline Translation: (("seizures"[MeSH Terms] OR seizure[Text Word]) AND (((("diagnosis"[Subheading] OR "prognosis"[MeSH Terms]) OR "physical examination"[MeSH Terms]) OR "diagnosis"[MeSH Terms]) OR diagnosis[Text Word])) Yield: 15,226 citations (Citations not examined) Search Four Pub Med Search Terms: "seizures and management" Medline Translation: (("seizures"[MeSH Terms] OR seizure[Text Word]) AND management[All Fields]) Yield: 1,140 citations (Citations not examined) Search Five Pub Med Search Terms: "epilepsy and practice guidelines" Medline Translation: (("epilepsy"[MeSH Terms] OR epilepsy[Text Word]) AND ("practice guidelines"[MeSH Terms] OR practice guidelines[Text Word])) Yield: 16 citations screened for relevant titles. Search Six Pub Med Search Terms: "epilepsy and guidelines" Translation: (("epilepsy"[MeSH Terms] OR epilepsy[Text Word]) AND (("standards"[Subheading] OR "Guidelines"[MeSH Terms]) OR guidelines[Text Word])) Yield: 352 citations screened for relevant titles. Summary Yield: 598 abstracts were searched for relevant titles. 24 full-text papers were retrieved for review.
3. AHRQ National Guidelines Clearinghouse (www.guideline.gov)
  - Yield: 2 useful guidelines on models of care in other disease settings (diabetes, asthma).
4. 1999 Cochrane Collaborative (CD-ROM database of systematic reviews)
  - Yield: 0 relevant titles.
5. www.epilepsy-international.com (conference abstract database)
  - Employed the following search terms: "epilepsy and management" "epilepsy and utilization" "epilepsy and guidelines" "epilepsy and referral" "seizures and management" "seizures and utilization" "seizures and guidelines" "seizures and referral"
  - Yield: 1 practice guideline; 15 abstracts.
6. MedScape (www.medscape.com)
  - Searched the clinical management and practice guidelines databases;
  - Yield: no relevant materials.
7. Epilepsy Foundation of America (www.efa.org)
  - Search of web site produced no relevant materials;
  - Information specialist is currently searching EFA database for disease management guidelines and referral criteria.
8. General WWW Search
  - Employed the terms "epilepsy and clinical management."
  - Yield: 1 practice guideline, 1 abstract.
9. Epilepsy Management Guidelines from Companies To find epilepsy management guidelines or referral criteria from companies producing epilepsy drugs, they were contacted by telephone. Below you will find the five companies that were contacted and the information they provided. Wallace Laboratories (1-800-526-3840) Drug: Felbamate The company does not have any pertinent information. Parke-Davis (1-800-223-0432) Drug: Gabapentin A representative from the Medical Affairs department said that they have no relevant information. Glaxo Wellcome (1-888-talk-2gw) Drug: Lamotrigine The Medical Department occasionally produces disease management information. In the case of epilepsy, they do not have anything other than package inserts for their drug. McNeil/Ortho Pharmaceutical Corp. (1-800-682-6532) Drug: Topiramate The medical specialist who answered the call is not aware of any disease management information that McNeil/Ortho may have produced. He will research it further and contact us if any relevant information becomes available (called on 03/23/99). Abbott Laboratories (1-800-255-5162) Drug: Tiagabine The customer service department communicated our needs to the sales department, which may have some type of information regarding epilepsy management guidelines. A voicemail was left for the sales department representatives and hopefully they will get back to MetaWorks with an answer as soon as possible (called on 03/23/99).
10. Manual Bibliography Search Yield: 2 papers.
11. Other sources: Lovelace Clinic Foundation Diagnostic/Treatment Algorithms

#### Full-Length Publications Retrieved and Reviewed

Citations Obtained from Medline Searches and Manual Bibliography Checks

##### General Models of Care/Disease Management

Arceci, R.J., Reaman, G.H., Cohen, A.R., and Lampkin, B.C. Position statement for the need to define pediatric hematology/oncology programs: a model of subspecialty care for the chronic childhood diseases. Journal of Pediatric Hematology/Oncology 1998; 20:98 - 103.

Bernard, D.B., Townsend, R.R., and Sylvestri, M.F. Health and disease management: what is it and where is it going? What is the role of health and disease management in hypertension? American Journal of Hypertension 1998; 11:103S - 108S.

Ferranti, S.D., Ioannidis, J.P.A., Lau, J. et al. Are amoxycillin and folate inhibitors as effective as other antibiotics for acute sinusitis? A meta-analysis. British Medical Journal 1998; 317: 632 - 637.

Glasgow, R.E. A practical model of diabetes management and education. Diabetes Care 1995; 18: 117 - 126.

Klinkman, M.S. Competing demands in psychosocial care - A model for the identification and treatment of depressive disorders in primary care. General Hospital Psychiatry 1997; 19: 98 - 111.

Link, M.P., Donaldson, S.S., Berard, C.W., et al. Results of treatment of childhood localized non-Hodgkin's lymphoma with combination chemotherapy with or without radiotherapy. New England Journal of Medicine 1990; 322: 1169 - 1174.

Nonas, C.A. A model for chronic care of obesity through dietary treatment. Journal of the American Dietetic Association 1998; 98 Suppl 2: 16 - 22.

Piro, L. and Doctor, J. Managed oncology care: the disease management model. Cancer 1998; 82 Suppl: 2068 - 2075.

Pritchard, J., Stiller, C.A., and Lennox, E.L. Overtreatment of children with Wilms' tumor outside pediatric oncology centers. British Journal of Medicine 1989; 299: 835 - 836.

Rand, E.H. and Thompson, T.L. Using successful models of care to guide the teaching of psychiatry in primary care. Psychosomatics 1997; 38: 140 - 147.

Roman, S.H. and Harris, M.I. Management of diabetes mellitus from a public health perspective. Current Therapies for Diabetes 1997; 26: 443 - 474.

Yang, Y.M., Shah, A.K., Watson, M., and Mankad, V.N. Comparison of costs to the health sector of comprehensive and episodic health care for sickle cell disease patients. Public Health Reports 1995; 110: 80 - 86.

#### Models of Care in Epilepsy

American College of Emergency Physicians. Clinical policy for the initial approach to patients presenting with a chief complaint of seizure, who are not in status epilepticus. Annals of Emergency Medicine 1993; 22: 875 - 883.

American Electroencephalographic Society. Guideline twelve: guidelines for long-term monitoring for epilepsy. Journal of Clinical Neurophysiology 1994; 11: 88 - 110.

American Electroencephalographic Society. Guideline fifteen: guidelines for polygraphic assessment of sleep-related disorders (polysomnography). Journal of Clinical Neurophysiology 1994; 11: 116 - 124.

Baraff, L.J., Schriger, D.L, and Starkman, S. Compliance with a standard for the emergency department management of epileptics who present after an uncomplicated convulsion. Annals of Emergency Medicine 1990; 4: 367 - 372.

Beghi, E, and Perucca, E. The management of epilepsy in the 1990s. Acquisitions, uncertainties, and priorities for future research. Drugs (Practical Therapeutics) 1995; 49: 680 - 694.

Betts, T. Epilepsy services. What people need, what they want, what they get. Acta Neurology Scandinava 1992; 140 Suppl: 95 - 100.

Brodie, M.J., Shorvon, S.D., Canger, R., et al. ILAE Commission Report: Commission on European Affairs -- Appropriate Standards of Epilepsy Care Across Europe. Epilepsia 1997; 38: 1245 - 1250.

Brown, S., Betts, T., Chadwick, D., et al. An epilepsy needs document. Seizure 1993; 2: 91 - 103.

Callaghan, N. The role of the neurologist in epilepsy management -- A neurologist's view. Seizure 1994; 3: 81 - 83.

Commission on Antiepileptic Drugs of the International League Against Epilepsy. Guidelines for Clinical Evaluation of Antiepileptic Drugs. Epilepsia 1989; 30: 400 - 408.

Commission on Antiepileptic Drugs of the International League Against Epilepsy. Guidelines for Therapeutic Monitoring on Antiepileptic Drugs. Epilepsia 1993; 34: 585 - 587.

Commission on Neuroimaging of the International League Against Epilepsy. ILAE Commission Report: Recommendations for Neuroimaging of Patients with Epilepsy. Epilepsia 1997; 38: 1255 - 1256.

De Boer, H.M., Aldenkamp, A.P., and Overweg, J. Epilepsy Care in the Netherlands. Acta Neurology Scandinavia 1992; 140 Suppl: 101 - 105.

Dreifuss, F.E. Epilepsy: standards of medical care. Medicine and Law. 1997; 16: 225 - 233.

Engel, J. Jr., Burchfiel, J., Ebersole, J., et al. Long-term monitoring for epilepsy. Report of an IFCN committee. Electroencephalography and Clinical Neurophysiology 1993; 87: 437 - 458.

Forsgren, L. Prospective incidence study and clinical characterization of seizures in newly referred adults. Epilepsia 1990; 31: 292 - 301.

Frith, J.F., Harris, M.F., and Beran, R.G. Management and attitudes of epilepsy by a group of Sydney general practitioners. Epilepsia 1994; 35: 1244 - 1247.

Gehlert, S. Perceptions of control in adults with epilepsy. Epilepsia 1994; 35: 81 - 88.

Graves, N.M., Gidal, B.E., and Gilliam, F.G. The new generation of antiepileptic drugs: unresolved questions. The Annals of Pharmacotherapy 1998; 32: 1239 - 1243.

Henneman, P.L., DeRoos, F., and Lewis, R.J. Determining the need for admission in patients with new-onset seizures. Annals of Emergency Medicine 1994; 24: 1108 - 1114.

Hughes, A.P., and Appleton, R.E. Epilepsy in a children's hospital: an out-patient survey. Seizure 1995; 4: 279 - 285.

Korpinen, L., Pietila, T., Peltola, J., et al. Evaluation of epilepsy expert -- a decision support system. Computer Methods and Programs in Biomedicine 1994; 45: 223 - 231.

Lammers, M.W., Hekster, Y.A., Keyser, A., et al. Clinimetric analysis of treatment objectives and clinical status: individualized treatment in epileptic patients. Epilepsia 1994; 35: 1271 - 1278.

Lesser, R.P. The role of epilepsy centers in delivering care to patients with intractable epilepsy. 1994; 44: 1347 - 1352.

Lough, M. A protocol for care. The Practitioner 1993; 237: 484 - 488.

Marks, W.J. Management of seizures and epilepsy. American Family Physician 1998; 57: 1589 - 1604.

National Association of Epilepsy Centers. Recommended Guidelines for diagnosis and treatment in specialized epilepsy centers. Epilepsia 1990; 31 Suppl 1: 1 - 2.

Nicolaides, P., Appleton, R.E., and Beirne, M. EEG requests in pediatrics: an audit. Archives of Disease in Childhood 1995; 72: 522 - 523.

Olejniczak, P.W., Carey, M.C., Fisch, B.J., et al. The Louisiana state university comprehensive epilepsy program: procedures and outcomes. Journal of the Louisiana State Medical Society 1996; 148: 525 - 532.

Osservatorio Regionale per l'Epilessia (OREp), Lombardy. The contribution of tertiary centers to the quality of the diagnosis and treatment of epilepsy. Epilepsia 1997; 38: 1338 - 1343.

Perucca, E. Innovative monotherapy trial designs for the assessment of antiepileptic drugs: a critical appraisal. European Journal of Clinical Pharmacology 1998; 54: 1 - 5.

Pledger, G.W. and Kramer, L.D. Clinical trials of investigational antiepileptic drugs: monotherapy designs. Epilepsia 1991; 32: 716 - 721.

Provisional Committee on Quality Improvement, Subcommittee on Febrile Seizures. Practice parameter: The neurodiagnostic evaluation of the child with a first simple febrile seizure. Pediatrics 1996; 97: 769 - 775.

Rayport, M., Feka R., Fogelson, M.H., et al. Minimum care standards for epilepsy for Ohio. Epilepsy standards subcommittee, medical advisory committee of the bureau for children with medical handicaps, Ohio department of health. Ohio Medicine 1990; 86: 796 - 801.

Scambler, G. Patient perceptions of epilepsy and of doctors who manage epilepsy. Seizure 1994; 3: 287 - 293.

Schachter, S.C., and Yerby, M.S. Management of epilepsy: Pharmacologic therapy and quality-of-life issues. Postgraduate Medicine 1997; 101: 133 - 153.

Taylor, M.P., Readman, S., Hague, B., et al. A district epilepsy service, with community-based specialist liaison nurses and guidelines for shared care. Seizure 1994; 3: 121 - 127.

Tettenborn, B., and Kramer, G. Total patient care in epilepsy. Epilepsia 1992; 33 Suppl 1: S28 - S32.

Thapar, A.K. Care of patients with epilepsy in the community: will new initiatives address old problems? British Journal of General Practice 1996; 46: 37 - 42.

Wallace, H.K., Shorvon, S.D., and Hopkins, A. An audit of the organization of adult epilepsy services in the UK: a comparative review of epilepsy and general neurology clinics. Seizure 1997; 6: 185 - 191.

### Attachment B: Stakeholders

List of Attendees

CDC/AHCPR Stakeholder Committee Meeting

Criteria for Referral of Patients with Epilepsy

March 25, 1999 -- Philadelphia, PA

- I. Epilepsy Specialists
- Frank Gilliam, M.D. (UNABLE TO ATTEND)
- University of Alabama Epilepsy Center
- 1719 6th Avenue South, Suite 312
- Birmingham, AL 35294
- Greg Barkley, M.D.
- Comprehensive Epilepsy Program
- Henry Ford Hospital
- 2729 West Grand Blvd.
- Detroit, MI 48202

- II. Primary Care
- Patricia Dean, MSN, MS
- Program Manager
- Comprehensive Epilepsy Center
- Miami Children's Hospital
- 3100 S.W. 62nd Ave.
- Miami, FL 33155
- Louis Trost, M.D.
- Lovelace Family Practice - Westside
- 2929 Coors, N.W.
- Albuquerque, N.M. 87120

- III. Health Services
- Margaret Gunter, PhD
- Lovelace Clinic Foundation
- Education Bldg., 2nd floor
- 5400 Gibson Blvd., S.E.
- Albuquerque, N.M. 87108
- Suzanne Mercure
- Director of Consumer Programs
- Institute for Health Policy Solutions
- Principal, Barrington and Chappell
- 6023 Madison Overlook Court
- Falls Church, VA 22041

- IV. Neurology
- David G. Cook, M.D.
- Pennsylvania Hospital
- 8th and Spruce Street
- Philadelphia, PA 19107
- David A. Stumpf, M.D.
- Northwestern University Medical School
- Department of Neurology
- 645 N. Michigan Ave.
- #1058
- Chicago, IL 60611-2814

- V. Consumers/Advocates
- Linda Warner
- 9156 Jewel Lane North
- Forest Lake, MN 55105
- Joyce Bender
- Chief Executive Officer
- Bender Consulting Services, Inc
- Penn Center West III, Suite 223
- Pittsburgh, PA 15276

- AHRQ
- Harry Handelsman, D.O.
- Task Order Officer
- Agency for Health Care Policy and Research
- 6010 Executive Blvd., Suite 310
- Rockville, MD 20852

- CDC
- Patricia Price, D.O., FACPM
- Epilepsy Program Coordinator
- Centers for Disease Control and Prevention
- Division of Adult and Community Health
- 4770 Buford Hwy, NEMailstop K-45
- Atlanta, GA 30341
- Suzanne M. Smith, M.D., M.P.H
- Chief, Health Care and Aging Studies Branch
- Centers for Disease Control and Prevention
- Mailstop K-45
- Atlanta, GA 30341

- CDC Ex Officio
- David Thurman, M.D.
- Centers for Disease Control and Prevention
- National Center for Injury Prevention and Control
- 4770 Buford Highway, N.E.
- Mailstop F-41
- Atlanta, Ga. 30341
- (770) 488-4715+

- Leonard Davis Institute/University of Pennsylvania
- Jacqueline French, M.D.
- (Project Co-Investigator)
- University of Pennsylvania Medical Center
- Department of Neurology, 3 West Gates
- 3400 Spruce Street
- Philadelphia, PA 19104-4283
- Joanne Levy, MBA, MCP
- (Project Manager)
- Associate Director
- Leonard Davis Institute of Health Economics
- University of Pennsylvania
- 3541 Locust Walk
- Philadelphia, PA 19104-6218

- MetaWorks
- Sameer Chopra, MA
- (Project Manager)
- MetaWorks Inc.
- 470 Atlantic Ave, 10th floor
- Boston, MA 02210
- Rhonda Estok, RN, BSN, CNOR
- (Project Administrator/Manager)
- Clinical Information Specialist
- MetaWorks Inc.
- 470 Atlantic Ave, 10th floor
- Boston, MA 02210
- Susan Ross, M.D., FRCPC
- (Project Co-Director)
- Chief Scientific Officer
- MetaWorks Inc.
- 470 Atlantic Ave, 10th floor
- Boston, MA 02210
- Isabella Sledge, M.D.
- (Project Co-Investigator)
- Assistant Medical Director
- MetaWorks Inc.
- 470 Atlantic Ave, 10th floor
- Boston, MA 02210

### Attachment C: Stakeholders Meeting Agenda

AGENDA

CRITERIA FOR REFERRAL OF PATIENTS WITH EPILEPSY
AHCPR/CDC MULTIDISCIPLINARY STAKEHOLDER MEETING
METAWORKS
MARCH 25, 1999
8:00am | Introductions | I. Sledge, M.D.
8:15am | Project Background CDC/AHCPR Project Rationale and Objectives. | P. Price, D.O./S Smith, M.D.
| MetaWorks Process | S. Ross, M.D.
8:40am | Explanation of Preliminary Literature Searches and Findings | I. Sledge, M.D.
| Models of care in settings other than epilepsy Models of care for epilepsy
9:15am | (Introduction) | S. Smith, M.D.
| Lovelace Seizure Disorder Project Overview | M. Gunter, PhD
9:35am | Introduction to Discussion Questions | I. Sledge, M.D
See Enclosure A: Framework for Developing Referral Criteria for Epilepsy Management
10:00am | Break (15 minutes)
10:15am | Discussion of Stakeholder Experiences: The "Real" and the "Ideal" | J. French, M.D./I. Sledge, M.D.
| Discussion of Framework for Developing Referral Criteria for Epilepsy Management
| See Enclosure B: Real and Ideal Experiences With Referrals for Epilepsy Management
12 - 1:00pm | Lunch (1 hour)
1:00pm | Continued Discussion: Framework for Developing Referral Criteri | J. French, M.D./I. Sledge, M.D .
| Synthesis of Consensus Views
2:15pm | Break (15 minutes)
2:30pm | Formulation of Questions for Further Investigation | J. French, M.D./ I. Sledge, M.D.
| Relating Questions to Preliminary Evidence Findings
3:15pm | Closing Statements | S. Ross, M.D.
| Summary of Conclusions and Questions for Further Investigation

### Attachment D: Enclosure B ("Real" and "Ideal" Experiences with Referrals for Epilepsy Management)

ENCLOSURE B | Your perspective (please circle the one most applicable:
| consumer | provider (generalist/specialist) | administrator | researcher | payor/policy maker

"Real" and "Ideal" Experiences With Referrals for Epilepsy Management Circle All Answers That Apply

REAL WORLD (YOUR EXPERIENCE) | IDEAL WORLD (IF DIFFERENT FROM YOUR EXPERIENCE)
  I. CURRENT CARE
  Referred to [image] MORE SPECIALIZED CARE
  PATIENTS ARE REFERRED FOR SPECIALIZED CARE FOR THE FOLLOWING REASONS: | Initial Diagnosis | Unclear Diagnosis | Treatment Initiation | Treatment Failure: Efficacy | Treatment Failure: Side Effects
  PATIENTS ARE REFERRED FOR SPECIALIZED CARE FOR THE FOLLOWING REASONS: | Long-term Management | Need for Other Services | Insurance Coverage/ Reimbursement | | Patient Preference
  | other:_______________________________________
  WHAT CRITERIA ARE USED TO DETERMINE, THE TYPE OF SPECIALIZED CARE (GENERAL NEUROLOGIST, EPILEPTOLOGIST, EPILEPSY CENTER) TO WHICH THE PATIENT IS REFERRED? | Accessibility | Expertise/ Services Offered | Insurance Coverage/ Reimbursement | Patient Preference
  WHAT CRITERIA ARE USED TO DETERMINE, THE TYPE OF SPECIALIZED CARE (GENERAL NEUROLOGIST, EPILEPTOLOGIST, EPILEPSY CENTER) TO WHICH THE PATIENT IS REFERRED? | Collegial Relationship | other:_______________________________________
  | Initial Diagnosis | Unclear Diagnosis | Treatment Initiation | Treatment Failure: Efficacy | Treatment Failure: Side Effects
  | Long-term Management | Need for Other Services | Insurance Coverage/ Reimbursement | | Patient Preference
  | other:_______________________________________
  | Accessibility | Expertise/ Services Offered | Insurance Coverage/ Reimbursement | Patient Preference
  | Collegial Relationship | other:_______________________________________
  II. SPECIALIZED CARE
  Returned to [image] MORE GENERALIZED CARE
  PATIENTS ARE REFERRED FOR SPECIALIZED CARE FOR THE FOLLOWING REASONS: | Long-term Management | Need for Other Services | Insurance Coverage/ Reimbursement | Patient Preference
  PATIENTS ARE REFERRED FOR SPECIALIZED CARE FOR THE FOLLOWING REASONS: | Accessibility | Collegial Relationship | other:___________________________ ________________________________
  | Long-term Management | Need for Other Services | Insurance Coverage/ Reimbursement | Patient Preference
  | Accessibility | Collegial Relationship | other:___________________________ ________________________________

### Attachment E: Stakeholders' Meeting Transcript

AHRQ/CDC/MetaWorks Epilepsy Stakeholders' Meeting

Penn Towers Hotel, Philadelphia

March 25, 1999

1. Introductions/Participants Suzanne Smith, MD, MPH, Chief, Health Care and Aging Studies, CDC. Patricia Price, DO, Epilepsy Program Director, CDC. Frank Gilliam, MD, Epileptologist, University of Alabama Epilepsy Center (did not attend) David Cook, MD, Neurologist, University of Pennsylvania Medical Center. Jacqueline French, MD, Epileptologist, University of Pennsylvania Medical Center; Co-Principal Investigator. Margaret Gunter, PhD, Health Services Researcher, Lovelace Clinic Foundation. Greg Barkley, MD, Medical Director, Comprehensive Epilepsy Center, Henry Ford Health System. Suzanne Mercure, Institute Health Policy Solutions; (works with employers in purchasing Healthcare, developing standards and requirements for health plans, and assisting consumers with problems and issues; consultant). Harry Handelsman, DO, Task Order Officer, AHCPR. Louis Trost, MD, Family Practitioner at Lovelace; Co-Chairman of project for integrated epilepsy care. David Thurman, MD, Neurologist & Epidemiologist at CDC Injury Center. David Stumpf, MD, Pediatrician and Neurologist; participated in Academy of Neurologists Practice Guidelines Committee. Joyce Bender, President and CEO of Pittsburgh information technology consulting firm; Member Of President's Committee On Employment Of People With Disabilities ; epileptic patient. Linda Warner, Economist; Board member of Epilepsy Foundation; son has epilepsy. Patricia Dean, MSN, Nurse Practitioner at a comprehensive epilepsy center at Miami Children's Hospital; board member of Epilepsy Foundation. Joanne Levy, MBA, MCP, Project Manger, Leonard Davis Institute, University of Pennsylvania. Susan Ross, MD, Chief Scientific Officer, MetaWorks. Isabella Sledge, MD, Co-Principal Investigator, MetaWorks. Rhonda Estok, RN, Clinical Information Specialist, MetaWorks. Sameer Chopra, MA, Project Manager, MetaWorks.
2. Project Background (P. Price; S. Smith; S. Ross) P. Price (CDC)
  - 1997 Living Well With Epilepsy Conference -- 3 work groups (clincal, public health, advocacy)
  - Goal of clinical work group: no seizures + no side effects = control.
  - Barriers to achieving goal:
    a. Physicians and patients don't realize it's an achievable goal (need for public health messages);
    b. Physicians not familiar with important diagnostic/treatment issues;
    c. Patients do not receive integrated care (e.g., education and counseling);
    d. Restrictions on referral to specialists (in managed care capitated networks);
    e. Insurers make decisions without evidence;
    f. Outcomes' evidence not readily available;
  - Identifiable Needs:
    a. Testable management framework to guide clinicians, consumers, and advocates (supported by theory, experience, and expert opinion);
    b. Population-based strategy for optimal care of people with seizures. S. Smith (CDC)
  - Evidence will not provide all that is necessary. There are gaps and biases in published scientific literature, and it will be our task to also identify questions to be investigated by outcomes and health services researchers. S. Ross (MetaWorks Inc.)
  - Our goal is to develop a framework for organizing the "clinical processes" (including patient support and education) necessary to provide optimal care to patients with epilepsy.
  - This project will be carried out in two phases. Phase I, which includes a preliminary review of available evidence of models of care in epilepsy and other disease settings, this Stakeholder's Meeting, and a report presenting evidence and meeting summaries in addition to a framework and action plan for Phase II, will conclude with a formal meeting between MetaWorks, CDC and AHCPR. The project sponsors can use the report at the end of Phase I to decide whether to proceed with Phase II.
3. Explanation of Preliminary Literature Searches and Findings (I. Sledge) Literature Review
  - See attached presentation overheads; (Available upon request) Models in Alternative Disease Settings
  - Asthma
    a. Institute for Clinical Systems Integration practice guidelines recommend "step approach." Patient can manage disease;
    b. Does not mention, however, what type of specialist should be consulted or when;
  - Diabetes
    a. Existing guidelines from Diabetes Treatment Centers of America mention triggers for referral to different specialists (neurology/ophthalmology), but not evidence-based - based upon expert opinion;
    b. Diabetes Control and Complications Trial (DCCT) -
      1. Tight management of type 1 diabetics (10% of all diabetics) keeps blood sugar levels low over time.
      2. 4 models of care presented:
        - Intensive Care (endocrinologist and specialist team);
        - Co-management (primary care focused with referral specifications for specialty care);
        - Expert System (primary care with treatment algorithms for diabetic care);
        - Mini-Clinic (blocks of practice time carved out to bring in diabetics at one time - consulting specialists present).
      3. Important Message: stratification of patients for different levels of care.
  - Childhood Cancer:
    a. Important Observation: care in specialty center may decrease overall system costs (due to long-term reduction in morbidity and mortality).
    Disease Management Approach
  - Particular arrangements utilize a capitated approach for paying for the disease as a whole, not for particular services;
  - Someone manages care for patient and makes decision for type of care needed;
  - Models exist in cancer: chronic disease of high cost, high volume, and with complex management issues;
  - Referrals today are often tied to reimbursement;
  - Discussion Comment: (J. Bender): medical groups (not just MCOs) are sometimes offering care in this capitated method;
  - Discussion Comment: (D. Stumpf): Intervention in a small group of patients may make large changes (e.g. 10% of patients use 90% of resources);
  - Discussion Comment: Reimbursement decisions often made in isolation of total "systems" perspective - pharmacy benefits managers, those who collect utilization data, etc., perhaps make these decisions independently. Hence, the long-term cost-savings perspective (which includes lost work time and disability) is not always taken when decisions on reimbursement made. Disease Management and Epilepsy
  - Epilepsy: Scarce literature on how changing management/referral patterns can improve outcomes or decrease particular types of care utilization (long-term);
  - Several European models of integrated care are available in the literature:
    1. "Epilepsy Care in the Netherlands" (Netherlands, 1997)
      a. Survery of referral patterns/outcomes;
      b. All patients with seizures see neurologists;
      c. Only three specialized centers available;
      d. Mobile outpatient clinics with neurologist decreased admissions to specialized epilepsy centers;
    2. Survey of 14 Epilepsy Centers (Italy, 1997)
      a. Over 3000 patients completed >2 years of follow-up;
      b. Percent of patients achieving remission increased from 13% (prior to evaluation in center) to 28%.
    3. "Epilepsy Needs Document" (England, 1993)
      a. Patient always goes back to GP;
      b. Looked at incidence of epilepsy and how many patients are at each point in pathway;
      c. District epilepsy services - liaison nurses coordinate care between GP and specialist. Neurologist does not have sole care of patient, EVEN if they only have seizures/epilepsy;
      d. Regional guidelines take into account the availability of specialists;
      e. Patient keeps a card to assist communication between primary care physician and neurologist;
      f. Discussion Comment (G. Barkley): So few neurologists in Great Britain - perhaps a driving force for this kind of arrangement;
      g. Discussion Comment (I. Sledge): Region-specific guidelines - not published, but distributed to physicians in various regions.
    4. Scottish Intercollegiate Guidelines Network (SIGN) Recommendations
      a. Based on panel discussion, not a systematic review of available evidence;
      b. Assigned tasks to different types of providers;
      c. Suggests that roles of providers within health system should be clearly defined;
      d. National Health Service in Scotland provides universal coverage;
      e. Discussion Comment: If you deviate from referral paths/criteria, do you not get reimbursed?
      f. Discussion Comment: In a rationed system, you are limited on the number of particular tests, etc., you can use. After a certain amount, services are provided without further reimbursement.
    5. (USA) National Association of Epilepsy Centers - Referral Recommendations
      a. Provided a flow diagram and criteria for referral;
      b. PCP should refer for more specialized care if seizures are not controlled in 3 months;
      c. Neurologist should refer if no seizure control in 9 months;
      d. Discussion Comment (D. Cook): Does not address fact that there are easy and difficult patients. The goal is to find out which patients can and should be referred early. Patients often stratify very early as "easy" or "difficult" patients. Discussion Comments Following MetaWorks Evidence Review
  - Patients need early contact with someone who can say, "this is what you have, this is what you need."
  - People who need referral may not be referred perhaps because they are viewed as "not sick enough." Is it possible that only the very sick and the "squeaky wheels" get the specialized care they need in our health systems?
  - (D. Stumpf): looked at Medicare data in Chicago. Suggests that 10% of epileptic patients are consuming 90% of ER visits. That's one criteria for MCO's to monitor care, or for identifying patients for capitated care. We need to focus on the 10% of patients causing all of the resource utilization;
  - Some patients have infrequent seizures but frequently visit the ER. Other patients have frequent seizures but do not seek care. Such situations may be driven by the threshold of the patient and family to accept or react to seizures, their knowledge on what to do and where to go, and the local availability of care;
  - (G. Barkley): some of the "expensive" patients are not difficult to treat, but have been mistreated. Referred to Morrell papers about ER visits and the severity of epilepsy.
  - In managed care, an ER visit is often viewed as a care failure.
    a. Particular tests performed in the ER (CT, MRI, etc.) are expensive and may be completely unnecessary. Because a care-managing physician is not seen or present at the ER, crucial information (e.g., that particular tests may have already been recently performed) is absent.
    b. (J. French): A PCP or neurologist inexperienced with epilepsy may "panic" about the onset of seizures as much as a family learning to cope with the illness. That might explain why there are many instances where such physicians do not oppose their patients' visits to the ER.
  - Seizures are a symptom of multiple conditions. There is a great need to identify and understand the underlying illness that produces the seizures. Only certain providers have the ability and experience to accomplish this task.
  - (D. Stumpf): There is a tremendous need for data. Medicare/Medicaid data is perhaps the best outcomes data available. What kind of data do we need to get answers to our questions? (We can prepare hypotheses for outcomes research in addition to looking to the literature to identify patient groups who need referral.)
  - (D. Cook): There is data about prognosis that could perhaps allow one to predict who will have more problems in the course of their illness and who will not, and when such problems will occur;
  - (J. French): Cited the VA Coop study, which found that if a diagnosis of epilepsy is made, the choice of drug may surprisingly not be a significant factor in the patient's outcome (whether he/she is seizure free or not; the adverse effects of drugs will vary).
  - (D. Stumpf): What percentage of all patients with epilepsy in a population are being seen by neurologists/epileptologists? The literature published on patients reaching that level of care (perhaps the vast majority of available epilepsy literature) may be extremely skewed or biased. Only 20% of all patients reach that level of care...
  - (G. Barkley): Significant number of patients seen by specialists turn out not to have epilepsy (perhaps 25%). Data is skewed if we don't know who at the top of the funnel really has epilepsy. Proper diagnosis is essential. We have no idea what's out there at a population-level.
  - The Easy Part: identifying trigger groups who require specialized care.
  - The Harder Part: identifying a physician's comfort level with providing particular types of care at different levels.
4. Lovelace Seizure Disorder Project Overview (M. Gunter)
  - (S. Smith): Introduction of M. Gunter. 1n 1993, Lovelace embarked on a disease management program in epilepsy to improve the quality of care (assuming that cost savings would follow);
  - (M. Gunter): Lovelace Health System
    a. An integrated MCO in New Mexico;
    b. Spent time identifying the costliest diseases to manage. Epilepsy was not one of them, but one particularly influential individual was interested at looking at this condition. Most significantly, Novartis was willing to provide funding;
    c. Explored disease management philosophy, or the idea that improving quality of care will improve patient outcomes (and cost-savings will follow);
    d. 300 physicians on staff (multi-specialty practice);
    e. 1,600 network physicians;
    f. 229,000 member HMO;
    g. 1 (235-bed) acute care hospital;
    h. 9 primary care centers.
  - VISION of project team: to provide high quality, efficient, timely healthcare for patients with seizure disorder with emphasis on empowerment of patients and their primary care providers;
  - MISSION is to excel at seizure management. And, most importantly, improve quality of life of suffering patients;
  - Disease Management Teams were cross-functional/multidisciplinary (primary care, specialists, pharmacologists, nurses, and administrators); they have research fellows and data technicians to collect data, in addition to outcomes support from researchers at Novartis;
  - Major Question: how do we eventually facilitate the use of guidelines after they are developed?
  - Development Phase: development of guidelines that combined evidence-based Identifying and principles and expert consensus. Pilot tested when completed.
  - Tracking potentially epileptic patients:
    a. Requires a good data system to enable the electronic identification of patients;
    b. Identification markers included ICD-9 codes (780.3, 345 series: diagnosis of epilepsy), CPT-4 codes (particular diagnostic tests such as EEGs), and prescriptions for antiepileptic drugs;
    c. All three flags gave an 89% yield in identification of epileptic patients;
    d. Medical record review.
  - Data collection:
    a. Patient specific:
      1. Humanistic component: QOLIE-31 questionnaire (patient satisfaction assessment) sent after patient confirmed as having epilepsy. Responses revealed that patients are not receiving satisfactory education materials on epilepsy;
      2. Clinical component: medical record review;
      3. Economic component: cost of epilepsy patients determined from utilization data;
    b. Provider specific: mail and telephone surveys for providers -- how comfortable are you with your knowledge about epilepsy? The surveys asked questions on provider knowledge across a wide range of seizure disorder work-up and management decisions and also requested advice on the tools that could be developed to help physicians do a better job.
  - Practice Guidelines Products:
    a. Adult new-onset algorithm with chronic management;
    b. Pediatric new onset algorithm with chronic management;
    c. ER new onset algorithm;
    d. Status epilepticus algorithm.
  - Guidelines: include referral criteria. Not worded as "this is what you must follow" but rather as "consider this approach and these suggestions..." which have been developed by a team of your colleagues in the system.
  - Some neurologists are very comfortable with epilepsy and some not. The same is true for PCPs.
  - Simply mailing guidelines to physicians will not improve care or change provider behavior;
    1. How do we help physicians provide better care? (and, at the same time, not be burdensome);
    2. Physicians appear to need trainingin addition to information or algorithms. Training components included:
      a. "Pearls" page;
      b. Laminated pearls card;
      c. Appendices (drug information, seizure characteristics, women of child-bearing age, blood level monitoring);
      d. History forms (initial history, follow-up history) so nothing is forgotten;
      e. QOLIE-10 (quality of life forms);
      f. Health risk assessment;
      g. Case studies.
  - Implementation:
    1. Pilot guidelines tested at 3 sites;
    2. Revisions were made based on feedback;
    3. Practice guideline presentation at organization-wide training sessions;
    4. Development team went to the physicians, rather than vice versa. The result: 80% provider participation in pilot program;
    5. Need local "champs" at each satellite/pilot clinic to carry torch and assist implementation efforts.
  - Key indicators of improvement:
    1. Quality of life;
    2. Improvements in processes:
      a. better outcomes documentation;
      b. work-ups follow guidelines recommendations;
    3. Patient/provider satisfaction;
    4. Improvements in provider comfort level.
  - Accuracy of electronic identification efforts:
    1. Total patients: 2756 (AED, ICD-9, CPT-4s);
    2. Good positive predictive value of electronic data. (CPT and AED best);
    3. Sensitivity: If only looked at three measures, would get 60% of true epileptics.
  - Prevalence: 4.7 per 1000 patients (across all ages); high in 75+ males and children;
  - QOL (Patient) Survey:
    1. 779 patients provided surveys (450 replied);
    2. Frequency of seizures largely important (more significant than intensity);
    3. Socioeconomic status (medium importance);
    4. Co-morbidities (small to medium importance);
    5. For patients taking antiepileptic drugs, the frequency of seizures and adverse effects had large importance.
  - Provider Survey (PCPs):
    1. Assessed knowledge and comfort level with treatment and diagnostic work-up;
    2. Assessed when and why they refer patients for more specialized care.
    3. Those who did not attend presentation/training felt less comfortable, less knowledgeable (mailing guidelines clearly does not by itself change physician behavior).
    4. If a panel of physicians sees more patients, they report feeling more knowledgeable/comfortable.
  - Next steps:
    1. Impact analysis (measurement of outcomes, post-implementation):
      a. Provider survey;
      b. Case finding;
      c. Provider confirmation (of patients);
      d. QOLIE-31;
      e. Medical record review;
      f. Utilization analysis;
      g. Cost analysis;
    2. Reinforcement by local champions;
    3. What's best for patient/providers to help them provide more efficient, cost-effective care?
    4. What can be accomplished without overwhelming physicians?
    Discussion of Presentation
  - (H. Handelsman): What would you like to learn from the project at Lovelace? How satisfied are you with the outcomes of your program?
  - (M. Gunter/L. Trost): We would like to learn when patients should be referred and to whom they should be referred. The impact of the project is still to be measured. But doctors in the system are familiar with each others' credentials and experience and can trust skills of the guidelines committee. In the system, trust has replaced "rules" on how to refer or when to refer.
  - (M. Gunter/L. Trost): We don't know if the results will be applicable to other health care organizations. Lovelace is an isolated, staff-model system (owned by Cigna), and our experience might not be generalizable.
  - Guidelines should be established to ensure that everything that is needed for patient gets done (history, diagnostics), regardless of who does it.
  - Poor documentation was an impediment to effectively managing care and measuring outcomes. Hard to see if important issues were not properly being dealt with!
  - After training, PCP has better idea of what he/she should be comfortable doing and what he/she shouldn't.
  - (J. French): Is it more cost-effective to teach 100 PCPs to manage particular components of care for 1 - 2 epileptics, or more cost-effective to just refer all of the patients to 1 specialist? Because epilepsy is a low prevalence condition, maybe PCPs don't have to know as much about epilepsy as they know about asthma, diabetes, etc.
  - (S. Smith): Maybe specialized care is not the most cost effective way to diagnose and manage epileptics. We need data to support our hypotheses.
  - (M. Gunter): For treating asthma within the Lovelace system, we have achieved great success in sending patients to specialized clinics.
  - To measure improvement, we need patients to be meticulous about recording when they have seizures and and the ways in which their condition improves. This is a very difficult task for obvious reasons! BREAK
5. Discussion of Stakeholders' Experiences: the "real" and the "ideal" Stakeholders broke into groups to discuss their perspective on real and ideal world referral experiences, using a framework provided to each before the meeting (attached to this transcript). The groups reconvened and reported their views:

SUMMARY: Stakeholders' Real and Ideal-World Experiences With Referral

A. | B. REAL | C. IDEAL
D. Primary Care Physicians | - Large number of issues reflect why referrals are made (initial diagnosis, unclear diagnosis, treatment initiation, treatment failure: efficacy, treatment failure: side effects, long-term management, need for other services, insurance coverage/reimbursement, and patient preference);; - Most patients in managed care networks are referred back to generalized care after specialty care;; - Implicit assumption that generalized care knows what to do when referral back occurs. | - Referral reasons are situation dependent and heavily influenced by provider knowledge and comfort level;; - Reimbursement or insurance coverage should not be an issue;; - Patient preference should win.
E. Neurologists | - Neurologists are often the only doctor for patients suffering from seizures and provide a particular measure of primary care services;; - Hard to generalize when referrals occur in the current system: there is great variation in the practice style, ability, and comfort level of neurologist who provides care to epileptics. | - More specialized intervention should be sought at particular "break points" that may require expert knowledge / management: diagnosis, choosing medications, providing supplemental drugs such as folate/calcium, initial monitoring, managing comorbidities, counseling, and stopping medications.
F. | G. REAL | H. IDEAL
I. Primary Care Physicians | - Large number of issues reflect why referrals are made (initial diagnosis, unclear diagnosis, treatment initiation, treatment failure: efficacy, treatment failure: side effects, long-term management, need for other services, insurance coverage/reimbursement, and patient preference);; - Most patients in managed care networks are referred back to generalized care after specialty care;; - Implicit assumption that generalized care knows what to do when referral back occurs. | - Referral reasons are situation dependent and heavily influenced by provider knowledge and comfort level;; - Reimbursement or insurance coverage should not be an issue;; - Patient preference should win.
J. Neurologists | - Neurologists are often the only doctor for patients suffering from seizures and provide a particular measure of primary care services;; - Hard to generalize when referrals occur in the current system: there is great variation in the practice style, ability, and comfort level of neurologist who provides care to epileptics. | - More specialized intervention should be sought at particular "break points" that may require expert knowledge / management: diagnosis, choosing medications, providing supplemental drugs such as folate/calcium, initial monitoring, managing comorbidities, counseling, and stopping medications.
K. Epileptologists | - Receive referral of patients at all points in the course of their epileptic condition, and from all points in the system;; - Reimbursement is a huge reason behind why some patients are referred to epileptologists and why others are not;; - Epileptologists provide value-added services to patients who have only seen neurologists or primary care physicians;; - Referrals back to generalized care stem from physicians' desire to maintain collegiality. | - Referral back to generalized care should occur when patient has achieved remission of seizures with no side effects; or the patient is seen, evaluated, and a care plan for a neurologist can be formulated;; - Patients return to epileptologists when any problems arise under the care of a neurologist or primary care physician.
L. Health Services/Payors | - Currently, health plan and provider selection by employers is typically made in a complete vacuum of information;; - Network manager (plan or provider groups) have all of the needed skills and services;; - Consumers feel that seeing a specialist is the norm/necessity since they do not have knowledge of evidence-based practice. | - Expectations from providers need to be better defined by consumer groups;; - Particular referral patterns will be adopted only if they save total costs to the health care system.; - Specialized services do not have to be performed by specialists;; - Rely on the mantra: "Getting people treated in the right way, at the right time, with the right skills, in the right setting, with the right outcome, at the right price."
M. Consumers | - Patient referrals are fueled by dissatisfaction with outcome of current care;; - Patient preference is the main driver behind referrals;; - Access to advanced treatments also drive referrals. | - Patient should be provided enough education to know what services to expect from their providers;; - Proper decisions need to be made about control of seizures vs. drug side effects (individual providing care must be familiar with this concept);; - Referrals should be based upon meeting patients' goals for treatment.

Primary Care (L. Trost, I. Sledge)

- All of the issues listed on the survey sheets are currently taking place and reflect why referrals are made;
- In the ideal world, all of the referral reasons are situation-dependent and heavily influenced by provider knowledge and comfort level;
- Curbside consults = same level of care;
- Most patients in managed care networks are referred back to generalized care;
- Pediatricians hold on to patients longer than do providers of care to adults;
- Most effective efficacy path may actually raise costs. Let's consider efficacy, not cost, first;
- Is it worth educating PCPs or having them refer patients to specialists in every instance?
- Ideally, education for primary care providers is important even if only to reduce panic and improve triage;
- In the ideal world, reimbursement or insurance coverage should not be an issue;
- Patient preference should win in the ideal world;
- (L. Trost): Interesting concept from another meeting: Patient-centered practice policies should be based on what the patients need rather the role of particular providers. Guidelines daring to address "who" should emphasize competencies (Association of American Family Practitioners.)
- There is tremendous variation in practice style. It would make sense to study these differences and compare outcomes. High patient volume may lead to better outcomes; (there's a lot of literature in surgical specialties demonstrating that the more patients with a particular condition a provider sees, the better the outcomes).

Neurology (D. Cook, D. Stumpf)

- Diagnosis and treatment can be conceptualized as a timeline. Where are the weak-points where expert intervention would be necessary? Six break-points can be identified:

[image]

Researchable Question: Which patients are at risk for poor prognosis/problem courses? Can we classify patients by our ability to control their seizures?

Difficulty Experienced in Controlling Seizures of Particular Types of Patients

| Young | Old | Brain Lesion | Passive/Poor Response to Counseling
General | + | +++ | ++++ | +++
Focal | ++ | +++ | ++++ | +++

Issues to Consider When Discussing Referral at This Level of Care

- Thought process: there are some "low-hanging fruits" (patients whose seizures are easy to classify, control, and treat) who can be brought quickly to remission;
- Easy patients may not need to be referred (low hanging fruit), but they still need to be counseled;
- Are there variations in style of practice between neurologists? What are the differences?
- What dictates the choice between monotherapy vs. polytherapy?
- Organization of care... are "curbside" consults possible or not?
- Where is the waste in the system (use of ER, bad diagnosis, misuse of technology, duplicity of CT and MRI testing, overuse of EEG);
- Any breakdown at any point in the treatment timeline above triggers referral. (David Cook added the following comments in correspondence after the meeting: "I think that many GPs are not aware of when a breakdown occurs. Some of these 'breakdowns' may not cause seizures but may cause long-lasting problems in terms of difficulty with management and/or appropriate monitoring. Therefore, awaiting a breakdown in the system before the referral may be problematic.")
- Counseling takes lots and lots of time that a neurologist may not have (who will do it?);
- Our discussion is an issue regarding classification of patients: easy things that doctors can do vs. what needs to be done by other, more epilepsy-focused individuals;
- PRINCIPAL CARE ISSUE: Often patients don't go to PCP, but directly to neurologist who manages all care (because epilepsy is the primary concern). Neurologists have varying levels of comfort and expertise providing primary care (e.g., cholesterol management, pap smears, etc.) For a seizure-free patient, a neurologist can provide primary care and often does;
- (J. Stumpf, G. Barkley): Counseling concept -- sequential presentations (counseling). People can't assimilate important information all at once.

Epileptologists (J. French, G. Barkley)

- Variation in care is an important issue. Epileptologists receive patient referrals from all different points in the course of their epileptic condition. No matter which point of care a patient arrives, 90% of patients claim that they have little information or understanding about their condition and the necessary care they should seek;
- In the real world, reimbursement is a huge reason for why some people are referred to epileptologists and why others are not;
- No matter how good the care of the referring neurologist, there are always little things about management of patient that could be tweaked: epileptologists certainly provide value-added services;
- How to choose patients for referral that will most benefit from the epileptologist and his or her resources?
- There is a common misperception that the epileptologist charges more. Cost may hence be a confounding issue when making decisions about when to refer to such specialized care. The epileptologist charges about the same as a neurologist but provides more time and more specialized care to patients. Epileptologists don't make money based on number of patients they see in an hour. Most of the revenue at epilepsy centers comes from drug studies, surgery referrals, academic sources, etc. This arrangement is a luxury that people in office practice may not have;
- Why do epileptologists refer patients back to more generalized care? To maintain collegial relations. Difficult to get patients to go back! The patient realizes that so many important resources are available (social worker, psychologist, epilepsy nurse, etc.) at epilepsy centers. When they call in middle of night in case of an emergency, everyone who answers has some specialized epilepsy training;
- Other circumstances would warrant referral to more general care: remission of seizures without side-effects; the patient is seen, evaluated, and a care plan for a neurologist can be formulated. If any problems arise in long-term management, the patient can always be sent back to the epilepsy center;
- How do we get patients to drive the process of moving between different types of providers? Is this even a good idea? (Many patients are perhaps not as articulate and forthright as others);
- Empowering patients is very important in modifying patterns of care usage; patients need to know more about their condition;
- The mantra "seizure free with no side effects" often drives referrals. But there's a point where you have to consider the patient's quality of life and draw the line as to how intense or invasive the medical interventions will be;
- Do we control seizures to the patient's or physician's satisfaction? Patients should be educated enough to know what's best for them... and what to expect from their care providers;
- (S. Smith): "No seizures, no side effects" a physician-centered perspective when it emerged at the Orlando conference;
- (J. French): Physicians need to have realistic expectations. Probably 30% of patients will not achieve goal of "no seizures, no side effects."

Open Discussion

- Patients seem to have epiphanies about their condition at epilepsy centers. A multidisciplinary approach to patient care is clearly needed. People lose control in their lives because they are randomly attacked by a seizures - it's very different than, for instance, having predictable arthritis every morning, or having chest pain when exercising too hard (e.g., heart patients). Patients need knowledge to develop understanding about their lives and condition - this will lead to improved quality of life;
- Problem: sometimes doctors think they can be everything to their patients and don't refer;
- In Orlando, it came out in discussions that doctors were never referring well-informed patients to the epilepsy foundation for resources and information. Doctors can't assume that even these patients will not need support from other individuals. Doctor shouldn't feel that they have supplied all the information necessary for an epileptic to get by, because that is rarely the case;
- Phenytoin may not be the best drug of choice for all patients (adverse drug reactions), but it is the most commonly prescribed. Physicians are stubborn and need evidence-based information;
- Internet: source of both information and misinformation. Evidence-based information needs to become freely available via this medium. For instance, CDC needs to lead the way so people know where to turn when they have information needs;
- Many good practice guidelines (evidence-based) are available in other disease settings. Problem is how to implement and change behavior of everyone in a system who provides care. Need complex issues distilled to algorithms that can be easily followed in busy practice.

Health Services/Payors (S. Mercure, M. Gunter)

- Health plan and provider selection by employers is typically made in a complete vacuum of information. Employers simply assume that the health plan has important evidence-based information and is providing the right array of services and providers for patients within the plan. Employers do not feel the need for details;
- Cost-effectiveness and total health care costs are critical. The only way any referral patterns will be adopted is if they save total costs to the system and improve the quality of healthcare. Cost includes lost work time as well as direct health care expenditures;
- Employers will pay only if they know something is worth it. Is $5 in extra premium going to lead to better outcomes for employees and hence less days off from work?
- Health professions need to remove their own job title barrier problems. Rely on the mantra: "Getting people treated in the right way, at the right time, with the right skills, in the right setting, with the right outcome, at the right price;"
- Consumers buy into evidence-based practice ("I have to see a specialist"). Self-referral occurs when people make a fuss within their system;
- Patients may select plans based on relationships with particular providers, generalists or specialists;
- Expectations from providers need to be defined by consumer groups;
- Specialized services (e.g., education) do not necessarily have to be performed by specialists;
- Telephone conversations work well in organized systems (without a real referral). Cost-saving curbside consultations.

Consumers (L. Warner, P. Dean, J. Bender)

- Patient referrals are fueled by dissatisfaction with outcome of current care;
- Patient preference is the main driver behind referrals (and should be);
- Patient education fuels demand for appropriate care - often one call or the sound of the word "appeal" to an MCO gets them to pay;
- ER is a dangerous, undesirable place;
- Different patients have different thresholds and levels of education and preparation which also guide referrals;
- Common reason for referral: access to advanced treatments;
- Many people with epilepsy do not have PCPs but neurologists as their primary caregivers. Many advocacy groups want the specialist to be the gatekeeper. A dangerous trend for people with multiple conditions? Does this promote gaps in preventive care?
- Some doctors are satisfied with their control of seizures when in actuality, the seizures can be better controlled. It comes down to seizures vs. drug side effects... Satisfaction of patient will stem from them knowing this trade-off and accepting the right balance of intervention;
- There is still a lot of stigma against epilepsy - which prevents people from going to a doctor in the first place;
- Doctors and other health care workers often overreact to epilepsy/seizures - how are patients supposed to act and feel? Education of the primary care givers is extremely important;
- What is patient's goal (for treatment)? This has to be identified by providers AFTER the patient is educated. Quality of life vs. remission of seizures. What risk are patients willing to take to control their seizures?
- GOAL: "no seizures, no side effects" - a goal for most folks. A good piece of public education for patients and providers (that it is possible at all). Important for this word to be out there.

____________________

POST LUNCH

____________________

V. Approaches to Framework/Model for Referral Criteria (using best available evidence)

Referral Strategies That Could Be Utilized in Framework (J. French, I. Sledge)

1. Point of care - referral at important points in care that may require expert opinion and resources: first diagnosis, choosing medications, drug delivery, changing medications;
2. Time-based - no referral while patient is symptom free and without side effects Referral if remission/control of seizures not achieved in a particular amount of time;
3. Population-based - particular at-risk populations need referral (e.g., epilepsy in childbearing age, epilepsy with co-morbid condition, epileptic on three or more drugs, etc.);
4. Service-oriented approach - what can a PCP do? What facilities/resources/services are needed to be able to manage epilepsy? And where are they located? Patient referrals driven by availability of services.

Discussion

- How do we find evidence for particular referral paths? ("back door" approach);
- Strategies above are not necessarily mutually exclusive (particularly 1 and 3);
- Where do we think we can find evidence?
- What evidence will be useful to people whom we want to use the evidence?
- If no evidence available, then develop research questions...
- Who accredits epilepsy centers? What defines the resources available at the comprehensive epilepsy centers? National Association of Epilepsy Centers established expectations for the centers 10 years ago. Currently, there is no national standard established by a funder, government agency, etc;
- Goal for group: not to get locked into particular types of providers, centers, etc., since what they can deliver is varied across the United States;
- Focus on critical elements of care. Could centers help define what needs to be available for epilepsy patients?
- Where do patients get stuck when they really should be referred for further care? At a specialist or a generalist? Patients may get stuck when they don't realize that there are better services available. Consumer needs to be educated as to what the services are. Their own advocacy may drive treatment;
- The group representing consumers warned, however, that consumer driven health care is a blight on the system. Many people cannot speak for themselves to get what they need;
- (S. Ross) Strategies 3 and 4 seem complementary and researchable. Develop a menu of potentially important services, consider specific populations, and then bring a time model to the issue. These are researchable strategies... and it's easy to identify where the gaps are. This approach gets away from talking about specific types of providers.
- Need to survey evidence to back up pieces of the framework. Outcomes data will be a big missing piece of any puzzle, but outcomes studies are a second step needed to answer the question: "Will the evidence assembled have merit in real life?"
- Need to help: CONSUMERS, PRIMARY CARE PROVIDERS, and INSURERS make decisions about referral. We have to get them information in a concise, logical way...
- Stumpf warns that the existing literature is published mainly by neurologists and subspecialty neurologists whose patient populations are small subsets of the real population. How to develop population-based guidelines from skewed evidence?

Populations Who May Need Referral for More Specialized Care

(Numeric ranking shown below is derived from a consensus vote and indicate research priority based on potential impact on healthcare systems, patients, and providers)

Note: Support system should be independent variable for every population category.

(1) All those undergoing 1^st^ diagnosis (children, adults, elderly) : Patients presenting with seizures could have any one or more of a number of different conditions. Someone needs to interpret different types of diagnostic information to classify the seizures. Are there predictors of changing diagnosis? Features to search in the literature: epidemiology (including misdiagnosis), history, work-up results, differential diagnosis, initiation of treatment, and venue of first diagnosis (ER or office, for instance).

Women with epilepsy (peri-childbearing, peri-menopausal)

Elderly patients

Patients presenting with febrile seizures

(3) Patients with comorbidities (brain injured stroke, motor syndromes, mental retardation, etc.): More likely to need specialized care to manage seizures or both conditions simultaneously.

(4) Patients demonstrating intractability

Patients with drug interactions

(4) Patients with side effects from Antiepileptic Drugs

(5) Withdrawals of Antiepileptic Drugs (Adult, Child)

Discussion

- (D. Stumpf) was concerned that there is not even sufficient data to show that EEGs are important to improving patient outcomes. Stumpf was very concerned that there is not enough data out there to create a menu of services required for the diagnosis of epilepsy;
- (J. French) agreed in part, but suggested that part of our responsibility to find out where further studies are needed;
- (D. Stumpf) thought of this project as a hypothesis-testing exercise.
- (S. Smith) reminded the group that this is neither a hypothesis-testing or hypothesis-generating exercise, but a policy planning exercise;
- (G. Barkley) refers to an organization of care in epilepsy article by Gruman in the Journal of Ambulatory Care Managment (S. Smith has the paper);

Menu of Services

First Diagnosis

General categories of things to look at:

- Technology
- Therapy
- Differential Diagnosis
- History
- Epidemiology
- Work-up

Things that need to be done:

- Take history
- Full physical
- Work-up (lumbar taps, blood work)
- Counsel the patient
- OT, PT, speech and language assessment

Things that might need to be available:

- EEG
- Scans (CT, MRI)
- Someone with knowledge of AEDs
- Someone with knowledge of classification
- Special EEGs with invasive monitoring, video monitoring, etc.

Discussion

- There's a lot that can be done at the time of first diagnosis that can save $$ and improve outcomes down the line.
- Issue: do we need evidence for what's needed to make a diagnosis of the first seizure in a population? The literature on comparative diagnostics is enormous.
- Is there evidence to show what services/resources should be on the menu? Is that what we need to look at?
- Problem: If roles are not established alongside what needs to be done, then people who are unqualified to perform certain roles may end up performing them but incorrectly... but the literature is not likely to be there to support how comfortable or knowledgeable physicians feel about making diagnosis. This will be a major gap.
- Consumers (or payors) can be alerted to know that there are questions that should or can be asked to a provider.
- Issue: incorrect diagnosis is a huge issue. Where do we draw the line when talking about diagnosis? Should we look at related disease states to dig up people who are epileptics but misdiagnosed? (e.g., look up syncope and see how many people are epileptic.)
- We need to alert people that misdiagnosis is extremely common and that there are consequences.

VI. Next Steps (S. Ross)

- Meeting report will go to CDC/AHCPR for review;
- Final meeting in Phase I will occur in April/May;
- This will be followed by a go-no-go Phase II decision by the CDC;
- Suggest a framework for organizing researchable issues by doing a cross tab of item 3 (populations) and 4 (services). Each selected cell in the matrix could be researched for quantity and quality of evidence available in literature.

VIII. Epilogue (CDC/AHCPR/MW/LDI organizers)

By next week :

- MW will develop the cross tab framework described above;
- MW will produce and distribute meeting transcript;
- We will all continue weekly meetings but with potential change of day and time;
- CDC will send MW a copy of Gruman paper referenced earlier: (Gruman J., VonKorff M., Reynolds J., Wagner E.H., and Barkley G.L. Organizing health care for people with seizures and epilepsy. J Ambulatory Care Manage 1998; 21/2: 1 - 17.

According to Task Order timeline:

- MW will develop and submit first draft of Final Report on Phase I of Task Order;
- MW will coordinate all schedules for Phase 1 close-out meeting in Washington, DC to review Report & Recommendations for Phase II.

N. IX. Draft Sample Matrix for Evidence Review

Services (Human and Resources)
Populations | HISTORY | LAB TESTS | SCANS | EEG | COUNSELING
1 (1^st^ diagnosis) 2 (intractability) 3 (co-morbidity) 4 5 etc. | Each cell exploded to reveal evidence or lack thereof (and need for outcomes)

### Attachment F: Matrix - Healthcare Services and Resources

Healthcare Services and Resources
DIAGNOSIS
Population | History | Neuropsychological Assessment | Physical Exam | Imaging | Imaging | EEG | EEG | EEG | EEG | Lumbar Puncture | Routine Blood Work
Adult & Pediatric | | | | CT | MRI | Standard | Video | Invasive | Prolonged Ambulatory Monitoring
Patients Undergoing First Diagnosis
Patients Demonstrating Intractability
Patients Presenting With Comorbities
Patients With Side Effects from AEDs
Patients Withdrawing From AED Therapy

Legend: This matrix was created to provide a framework for evaluating the quantity of evidence pertaining to various healthcare services and resources (x-axis) as well as patient populations of interest (y-axis). The populated framework matrix can be found in Appendix B. Grey areas represent assumptions of non-applicability or minimal evidence, but did not prohibit the inclusion of evidence found on these topics.

## Appendix 2 Populated Matrix -- Potential Literature Available

[image]

The cells contain the number of applicable citations as determined by the screening and categorizing of abstracts (see "Literature Search" for more information). For example, the highlighted box "123" pertains to the number of studies addressing the value of history-taking in the care of patients undergoing first diagnosis of epilepsy.

[image]

The cells contain the number of applicable citations as determined by the screening and categorizing of abstracts (see "Literature Search" for more information). For example, the highlighted box "3" pertains to the number of studies addressing the value of standard EEG during the monitoring of patients undergoing first diagnosis of epilepsy.

[image]

The cells contain the number of applicable citations as determined by the screening and categorizing of abstracts (see "Literature Search" for more information). For example, the highlighted box "117" pertains to the number of studies addressing the value of pharmacologic expertise during the treatment of patients who have undergone their first diagnosis of epilepsy.

## Appendix 3

### Critical Questions for Systematic Review AHCPR/CDC Epilepsy October 20, 1999

#### Population 1: Patients Undergoing First Diagnosis

Primary Question: What elements (expertise, services, tests) may be needed to make the first diagnosis and initiate and monitor optimal treatment?

1. For the following tests. . .
  - Standard/Routine EEG
  - Ambulatory EEG
  - Video-EEG Monitoring
  - Invasive EEG
  - CT
  - MRI
  - Lumbar Puncture
  - Blood Testing
  - What is the cumulative contribution (in order of increasing invasiveness and cost) of each of the following diagnostic interventions to the accurate diagnosis of patients presenting with their first seizure?
  - What are the positive and negative predictive values of each test alone?
  - In what instances do additional tests add little useful information?
  - Is there evidence that not applying particular tests will lead to incorrect diagnosis, negative health or negative psychosocial outcomes?
  - Are these tests useful for all patients undergoing first diagnosis, or only particular sub-populations?
  - Which components of the patient's history are necessary to accurately diagnose the first seizure?
2. What criteria should be used to guide decisions regarding the timing and selection of treatments for patients undergoing first diagnosis?
3. Which interventions are necessary to adequately monitor patients on their first epileptic drug regimen? To ensure that the first diagnosis was correct? For what period of time should this monitoring occur? Should such monitoring be routine or prompted by particular symptoms/events?
4. What aspects of pharmacological expertise have been demonstrated to result in optimal patient outcomes (maximum reduction of seizure frequency with minimal side effects)? (pharmacological expertise: selection of optimal AED based on epilepsy diagnosis and patient characteristics; adjusting drugs and dosages to reduce seizures; monitoring and limiting adverse drug reactions and interactions; monitoring patient's tolerance and compliance with particular drug regimens; recognizing changes in seizure characteristics; ordering and interpreting appropriate lab tests based on knowledge of specific adverse events associated with different drugs).
5. What social services are necessary for patients at the time of first diagnosis? Employment counseling? Assistance/information from the Epilepsy Foundation? And is there evidence demonstrating that counseling improves patient follow-up, compliance and quality of life?

#### Population 2: Patients Demonstrating Intractability

Primary Question: What elements (expertise, services, tests) may be needed to identify and care for intractable patients?

1. How should intractability be defined?
2. Is there evidence that a lack of particular expertise, services, or tests will lead to improper management or negative outcomes?
3. What is the contribution to appropriate diagnosis/treatment of the following tests: routine EEG, ambulatory EEG, video-EEG monitoring, CT, MRI (with special protocols such as FLAIR), PET, and specialized drug monitoring?
4. What interventions should be available to confirm diagnostic suspicions of intractability due to incorrect initial diagnosis? Due to inappropriate treatment?
5. When should the following treatment interventions be available to intractable patients: investigational drug studies, surgical evaluation, vagal nerve stimulation, neuropyschological testing, and social work? In what order? And how should intervention outcomes be evaluated?
6. How long should a patient be followed without improvement before the next level of care is sought?

#### Population 3: Patients Presenting With Comorbidities

Primary Question: What elements (expertise, services, tests) may be needed to care for patients with comorbidities?

1. What monitoring interventions are appropriate for pregnant women with epilepsy? What AEDs? What special counseling?
2. What counseling and/or testing should be offered to men with epilepsy on AEDs, with regard to endocrine status, fertility, and reproductive outcomes?
3. Are children of epileptic women (or men) in need of special diagnostic tests? Monitoring? What is the incidence of congenital anomalies? Are long term developmental outcomes similar to children without epilepsy?
4. Are children with mental retardation more likely to suffer epilepsy? Are there specific diagnostic or monitoring interventions that should be available to children with mental retardation or other neuropsychological disabilities to diagnose epilepsy? Do these children require special treatments?

#### Population 4: Patients With Side Effects from AEDs

Primary Question: What elements (expertise, services, tests) may be needed to care for patients experiencing the adverse effects of anti-epileptic drug therapy?

1. What monitoring tools/resources best detect or predict the onset of AED-related adverse events?
2. Are AED side effects currently underdiagnosed?
3. What patient and treatment factors are associated with a higher risk of AED side effects? What diagnostic or monitoring interventions can best detect the side effects associated with particular patient or treatment factors? What pharmacologic expertise may prevent these side effects?
4. What is the appropriate management (diagnosis and treatment) of AED-related side effects? When should patients with side effects be referred?
5. What measures should be routinely employed to reduce the incidence of AED side effects?

#### Population 5: Patients Withdrawing from AED Therapy

Primary Question: What elements (expertise, services, tests) may be needed to care for patients withdrawing from anti-epileptic drug therapy?

1. Which patients may be safely withdrawn from AEDs? What diagnostic or monitoring interventions can identify such patients?
2. What monitoring interventions should be employed after withdrawal of AEDs?
3. What counseling should patients receive upon withdrawal of AEDs? What activity restrictions should be placed upon these patients?
4. When should treatments be reintroduced in patients who have withdrawn from AEDs?

## Appendix 4

### LEGENDDomains for Prioritizing Questions for Systematic Review

Purpose: To refine our literature review, members of the project technical expert panel (TEP) were asked to rate each population (and critical questions associated with that population) against the prioritization criteria listed on the y-axis (left-hand side) of the following spreadsheet. The cells of the spreadsheet contain aggregate TEP ratings. The tallies at the bottom of the spreadsheet facilitated the decision to pursue a systematic review of the literature concerning patients undergoing the first diagnosis of epilepsy ("Population One"). The critical questions relevant to each population can be found in Appendix C.

Population One: Patients undergoing their first diagnosis.

Population Two: Patients demonstrating intractability.

Population Three: Patients presenting with comorbidities.

Population Four: Patients with side effects from anti-epileptic drug therapy (AEDs).

Population Five: Patients withdrawing from AED therapy.

AHRQ Epilepsy - Technical Expert Panel Comains Results

Domains for Prioritizing Questions for Systematic Review - TEP RESULTS
AHCPR/CDC Epilepsy
| POPULATION 1 | | | | | POPULATION 2 | | | | | | POPULATION 3 | | | | POPULATION 4 | | | | | POPULATION 5
QUESTION # | 1 | 2 | 3 | 4 | 5 | 1 | 2 | 3 | 4 | 5 | 6 | 1 | 2 | 3 | 4 | 1 | 2 | 3 | 4 | 5 | 1 | 2 | 3 | 4
Please rate each question on a scale of 1 (not useful) to 10 (extremely useful) based on their relevance to the following topics:
Addressess an issue affecting largest number of epileptic patients | 76 | 73 | 64 | 66 | 64 | 36 | 38 | 32 | 32 | 27 | 48 | 35 | 37 | 48 | 28 | 63 | 64 | 63 | 59 | 56 | 55 | 39 | 42 | 34
Addresses the needs of older or poorer patients (Medicare/Medicaid) | 65 | 64 | 56 | 63 | 66 | 36 | 45 | 39 | 38 | 36 | 50 | 38 | 39 | 40 | 44 | 66 | 64 | 67 | 58 | 57 | 56 | 39 | 48 | 34
Addressess high current cost of care (or an issue with high potential cost savings) | 59 | 68 | 56 | 65 | 59 | 50 | 64 | 51 | 54 | 42 | 61 | 44 | 18 | 34 | 37 | 54 | 40 | 53 | 51 | 48 | 59 | 31 | 36 | 37
Recommendations likely to lead to improvement in quality of care or reduce practice variation | 61 | 70 | 69 | 68 | 54 | 72 | 69 | 63 | 61 | 56 | 60 | 64 | 47 | 47 | 42 | 64 | 51 | 63 | 56 | 58 | 67 | 54 | 45 | 35
Addresses an issue where implementation of evidence-based recommendations are likely | 65 | 62 | 58 | 65 | 42 | 61 | 62 | 61 | 59 | 53 | 57 | 61 | 27 | 40 | 41 | 52 | 48 | 50 | 47 | 46 | 56 | 44 | 39 | 39
Addresses an issue where impact of recommendations can be measured | 64 | 60 | 69 | 56 | 54 | 53 | 66 | 47 | 44 | 46 | 50 | 64 | 32 | 48 | 41 | 52 | 45 | 48 | 51 | 41 | 61 | 42 | 36 | 40
Potential for systematic reivew based on availability of evidence (CD-ROM, populated matrix) | 54 | 55 | 56 | 54 | 35 | 52 | 57 | 57 | 50 | 46 | 51 | 43 | 22 | 26 | 23 | 54 | 47 | 40 | 34 | 35 | 47 | 28 | 22 | 28
Column TOTALS | 444 | 452 | 428 | 437 | 374 | 360 | 401 | 350 | 338 | 306 | 377 | 349 | 222 | 283 | 256 | 405 | 359 | 384 | 356 | 341 | 401 | 277 | 268 | 247
Population TOTALS (average) | 2135 (427.0) | | | | | 2132 (355.3) | | | | | | 1110 (277.5) | | | | 1845 (369.0) | | | | | 1193 (298.3)

## Appendix 5

### Criteria for Referral of Patients with EpilepsyPhase II Work Plan: Part BNovember 23, 1999December 14, 1999 (Revision)November 23, 1999

#### 1.0 Introduction

The topic "Criteria for Referral of Patients with Epilepsy" was nominated by the CDC to support its efforts to determine effective care for persons with epilepsy. These criteria may be used as a framework for organizing the clinical processes necessary to provide optimal care for persons with epilepsy.

The project has been carried out in 2 phases. Phase I tasks were preparatory to a one-day meeting of diverse stakeholders, including epilepsy specialists, neurologists, primary care providers, health care systems representatives, and consumer advocates. The meeting resulted in a matrix framework of patient populations of interest, and health care services for each.

In Phase II, Part A, an initial assessment of the quantity of literature potentially available for each cell on the matrix was obtained (see Appendix 1). This work was described in the Work Plan dated May 24, 1999, with revision dated July 29, 1999. Questions regarding diagnosis, monitoring, and treatment services were then formulated to guide subsequent literature reviews in each patient population (see Appendix 2). Stakeholder feedback was obtained to help prioritize the questions, populations, and services along several domains (see Appendix 3). Phase II, Part A concluded with a joint decision made at a conference call October 29, 1999 to pursue a systematic review of the literature to answer questions referable to one population (persons with a first diagnosis of epilepsy) across all of the healthcare service questions posed. This selection was made because it received the highest priority ratings from stakeholders; it appeared to have sufficient literature available; and the remaining contract budget was sufficient to cover the anticipated work.

In Phase II, Part B, a systematic review of the literature will be performed. The following is the Work Plan for Phase II, Part B.

#### 2.0 Objective

The primary objective of Phase II, Part B of this project is to answer specific questions regarding diagnosis, monitoring, and treatment services needed by people with a first diagnosis of epilepsy. The following specific questions will be addressed in the systematic review:

1. What elements (expertise, services, and tests) may be needed to make the first diagnosis and initiate and monitor optimal treatment?
  a. For the following tests (EEG - standard, ambulatory, video, invasive -, CT, MRI, lumbar puncture, blood tests), what is the cumulative contribution (in order of increasing invasiveness and cost) of each of the interventions to the accurate diagnosis of patients presenting with a first diagnosis? Does timing or urgency of completion of tests affect decisions and/or patient outcomes? What is the positive and negative predictive value of each test alone? In what instances do additional tests add little useful information? Is there evidence that not applying particular tests will lead to incorrect diagnosis, negative health or negative psychosocial outcomes? Are these tests useful for all patients undergoing first diagnosis? Or only particular sub-populations? Which components of the patient's history are necessary to accurately diagnosis the first seizure?
2. What criteria should be used to guide decisions regarding the timing and selection of treatments for patients undergoing first diagnosis? Are all available treatment modalities being considered if seizures persist?
3. Which interventions are necessary to adequately monitor patients on their first epileptic drug regimen? To ensure that the first diagnosis was correct? For what period of time should this monitoring occur? Should such monitoring be routine or prompted by particular symptoms/events?
4. What aspects of pharmacological expertise have been demonstrated to result in optimal patient outcomes (maximum reduction of seizure frequency with minimal side effects)? (Pharmacological expertise = selection of optimal antiepileptic drugs (AEDs) based on epilepsy diagnosis and patient characteristics; adjusting drugs and dosages to reduce seizures; monitoring and limiting adverse drug reactions and interactions; monitoring patients' tolerance and compliance with particular drug regimens; recognizing changes in seizure characteristics; ordering and interpreting appropriate lab tests based on knowledge of specific adverse events associated with different drugs).
5. What social services are necessary for patients at the time of first diagnosis? Employment counseling? Assistance/information from the Epilepsy Foundation? And is there evidence demonstrating that counseling improves patient follow-up? Compliance? Quality of life?

#### 3.0 Methods

In general, MetaWorks will apply the latest and established best methods in the evolving science of review research ^(1 - 5)^. A flow diagram outlining the systematic review process is located in Appendix 4. The following tasks will proceed sequentially, and a project timeline is provided in Appendix 5.

Specific tasks are described below:

1. Phase II, Part B Work Plan Development and Topic Refinement 1a. MetaWorks will submit this Phase II, Part B Work Plan as a draft to the AHCPR TOO and CDC for approval. The Work Plan will also be sent simultaneously to the TEP (as constituted in Phase II, Part A - see list of names in Appendix (6) for review and feedback. Feedback will be incorporated as appropriate. 1b. In addition to the TEP, MetaWorks will identify up to 12 individuals who are expert in the topic area, to serve as peer reviewers of the draft evidence report. MetaWorks will submit the names of these experts and organizations to the TOO and CDC for approval. 1c. MetaWorks will then review existing evidence in order to:
  1. assess the incidence and prevalence of persons with a first diagnosis of epilepsy, including the characteristics and size of the affected populations(s) and presence of specific high-risk groups.
  2. assess the burden of illness associated with a first diagnosis of epilepsy, including morbidity, mortality impact on developmental milestones, quality of life, loss of productivity, medical costs to diagnosis and treat, and other economic costs or burdens associated with a first diagnosis of epilepsy.
  1d. With input from the TEP, MetaWorks will specify a causal pathway that identifies the critical diagnostic, monitoring, and treatment services for this specific population and links them to desired patient outcomes. 1e. MetaWorks will submit a report on results of subtasks 1b-d to the TOO.
2. Literature Search, Study Selection, and Development of the Database MetaWorks' Medline search and screening of abstracts in Phase II, Part 1 of this Task Order, which covered the period 1980 to April 15, 1999, suggests there are approximately 400 unique citations to be further screened for inclusion in this review. This figure does not take into account the results of searching other bibliographic databases and manual searching, which will both be performed now. Nevertheless, from the Medline search and screening already performed, we estimate a 20% yield or 80 studies ultimately accepted for inclusion in the review. Each of these 80 may contain data addressing multiple services in multiple modalities (diagnosis, treatment, monitoring). MetaWorks will systematically review and assess the relevant scientific evidence for each question. In particular, MetaWorks will:
  1. Search MetaWorks will update the Medline search to November 1, 1999. It will also search Current Contents and the Cochrane Library, as well as a manual search of references from recent reviews (last 3 years) on the subject of first diagnosis of epilepsy. We will contact the TEP to identify any other relevant bibliographic databases and/or studies. In addition, Internet sites will be checked for potential leads to additional studies as well as to identify existing clinical guidelines, potentially important authors and special interest groups who may assist.
  2. Study Screening MetaWorks will download and print all abstracts not previously obtained for subsequent screening by the Project Team members. In some cases, it may not be possible from the abstract alone to determine the specific population, test, or outcome involved in the study. All abstracts lacking an obvious exclusion criterion, will be included for retrieval of full papers, if the categorization is unclear. Screening is typically a two level activity, where the librarian and research assistants on the team perform a Level I screen, whereby they reject abstracts which are obviously ineligible, such as animal studies or, for example, studies written in ineligible languages, e.g., Polish. Whenever there is doubt about eligibility based upon review of abstracts and/or titles, full papers are retrieved by the research assistants from the local medical libraries. The second level of screening (Level II) is typically performed by the investigator and any coinvestigators, and is performed on full papers. These reviewers check each paper against the inclusion and exclusion criteria as set out further below. Since study selection is a critical component of any systematic review, the Level II screen requires the agreement of 2 reviewers for each paper selected and rejected. In cases of disagreement, a third reviewer will adjudicate. In such cases, the questionable papers are typically set aside for use in subsequent sensitivity analyses of the outcomes, to determine what effect, if any, their inclusion and exclusion would have on the overall results.
  3. Study Selection See the Phase II, Part A Work Plan for Level I exclusion criteria already applied to all abstracts during Level I screening in Phase II, Part A. An additional exclusion criterion to be applied at Level II is that of studies where results for first diagnosis patients cannot be separated from results from other patient populations. Level II inclusion criteria are:
    - Study designs: observational [prospective, retrospective, and cross sectional], or interventional [randomized non-randomized controlled trials (non-RCTs), and uncontrolled case series (UCS)].
    - Adults or children with a first diagnosis of epilepsy.
    - Studies addressing any of the following diagnostic interventions: history, neuropsychological assessment, physical exam, imaging with CT, MRI, or PET scans, EEG (standard, video, invasive, ambulatory), lumbar puncture, or blood test.
    - Studies addressing any of the following monitoring interventions: EEG (standard, video, invasive, or ambulatory), lab tests (hematology/biochemistry) and drug assays (standard or sophisticated), and pharmacologic expertise.
    - Studies addressing any treatment intervention: pharmacological expertise, counseling/psychosocial, surgery (resective or vagus) PT/OT, speech language, investigational study, education.
    MetaWorks will submit to the TOO a summary of this literature screening phase, including total number of abstracts reviewed for this population, articles retrieved, eligible studies identified, and reasons for exclusion. MetaWorks will prepare study level evidence tables wherein key features of each accepted study are displayed. These will include lead author, year of publication, country of study, study design, total number of patients studied, main interventions studied, and the main outcomes available. These study level evidence tables will be submitted with the full bibliography of accepted and rejected studies to the AHCPR TOO for feedback. Also included will be MetaWorks' recommendations regarding changing direction or scope of the project based upon the findings.
  4. Data Extraction MetaWorks will next extract key data from each eligible study, and enter extracted data into an electronic database. Data extraction is accomplished by one researcher recording data from original reports onto a data extraction form (DEF), and consensed by a second researcher checking all DEF fields (both filled and blank) against the original report. Differences are resolved prior to data entry. DEFs are designed in advance, and pilot tested on a small sample of eligible studies. The pilot test allows for necessary edits to the DEF to be made prior to broad implementation on all studies. Dual review of all data serves to reduce error and bias in the data extraction process. Teams of data extractors ideally consist of one methodologist paired with one clinician. Data extraction forms (DEF) will be created specifically for this project. Data from each accepted study will be extracted onto the DEF independently by one reviewer and the completed DEF will be 100% checked against the original articles by a second reviewer. Any differences will be resolved by consensus, thus two reviewers must agree on all data. The data will then be entered in MetaWorks' relational database, MetaHub^™^. At this time, it is anticipated that the following data elements will be extracted: Study level characteristics
    - Publication year
    - Geographical location of study
    - Study design (retrospective observational, prospective observational, or prospective interventional - RCT, nRCT, UCS)
    - Methodological assessment
      - Level of Evidence (I-V) - all studies
      - Jadad Quality Score - RCTs
    - Total number (and per group) of patients enrolled
    - Total number (and per group) of patients lost to follow-up and withdrawn
    - Study duration
    - Accrual years (or interval of observation)
    - Primary study objective or endpoint (text)
    - Funding source/industry sponsorship (yes or no/NR)
    - Costs component available (yes/no)
    - Type of facility/institution (teaching, non-teaching, community, office or clinic, epilepsy center, other)
    Patient characteristics
    - Age: years (mean, median, and range)
    - Race (number per category: Caucasian/African American/Hispanic/Asian/Other)
    - Gender distributionm
    - Family history of epilepsy
    - Presentation (symptoms, observed events, other)
    - Presentation (first time vs. repeat or recurring events)
    - Physical findings (neurological, other)
    - Idiopathic vs. symptomatic epilepsy
    - First seizure type (convulsion vs. partial, etc.)
    - Provisional Diagnosis (classification system and assignment)
    Intervention Characteristics
    - Test Interventions (for diagnosis or monitoring)
    - EEG (standard, ambulatory, video, invasive)
    - CT
    - MRI
    - PET scan
    - lumbar puncture
    - blood tests (specify)
    - Timing of each of the above
    - Monitoring schedule (routine - with interval - or prompted)
    - Final Diagnosis (classification system and assignment)
    - Final Diagnosis changed from original (provisional) diagnosis? (yes, no)
    - Treatment Interventions (pharmacologic, counseling, neuropsychological, surgical, other)
    - Timing of treatment initiation (first presentation or subsequent)
    - Pharmacological expertise level reported (text)
    - Care provider (team or sole: primary care, internal medicine, general neurologist, epilepsy specialist, surgeon, radiologist, other)
    - Location of care
    Outcomes:
    - Optimal patient outcomes defined? If yes, text.
    - Optimal patient outcomes achieved? (# patients yes, no) and time of achievement.
    - Time zero for time to outcomes achieved.
    - Sensitivity and specificity of test interventions
    - Positive and negative predictive value of test interventions
    - Compliance measured and achieved, and method
    - Quality of life measured and achieved, and method
    (These preliminary selections may change prior to finalization of the DEF as a result of input from the TEP and/or subsequent revisions to this Work Plan during topic refinement).
  5. Quality Assessment At the time of data extraction, all studies will be appraised according to a previously published Level of Evidence (Appendix 7). Each accepted RCT will also be scored for quality (features of randomization method used, blinding of treatments, and accounting for all patients entered and withdrawn) by the Jadad Quality Score Assessment (Appendix 8). An Evidence Score will be computed for each study as the product of the Level of Evidence score by the Jadad score (if available). For studies with no Jadad score, the multiplier will be 1. Thus RCTs will be given a higher overall quality score than studies which are not RCTs. Evidence scores may be used as categorical or continuous variables in subsequent sensitivity analyses (e.g., multivariate regression analyses) or by exploring the impact of outliers upon the results. They are also important to consider in interpretations of the reliability and significance of the evidence available in support of any conclusions.
  6. Database Development All consensed data will be entered into the MetaWorks MetaHub^™^ database. Data entry is performed by 1 to 2 research assistants on the Project Team from a consensus version of the DEF for each included study. These research assistants have been trained and demonstrated competency in the entry of data to MetaHub.
  7. Database quality control 100% of entered data is checked back to the DEFs after each form is completely entered. In addition, a 20% random sampling of data in the completed database will be checked by the Quality Control (QC) group at MetaWorks against the data extraction forms. Again, all discrepancies in data are reconciled, if necessary by referring back to the original papers. Error rates in excess of 2% of checked data will trigger a 100% check of all data elements in the database. Once the accuracy of the database has been verified as described above, it is locked. No further changes are allowed after the data is locked. This is the dataset that will be used by the statisticians for any analysis, and to create raw data tables displaying key data elements of interest, by study.
3. Synthesis of Evidence This task involves bringing together all of the evidence into a coherent report and presenting the raw data in a tabular format as well as performing both qualitative and quantitative data syntheses as data permit and as protocol objectives require. MetaWorks will prepare and submit to the TOO evidence tables and summaries of estimates of important patient outcomes associated with epilepsy. At this time, MetaWorks will include a bibliography in computerized format of all literature abstracted for the evidence tables or used to develop the evidence. MetaWorks will also develop and submit for TOO approval its recommendations for any supplemental analyses, such as meta-analyses and/or cost analyses.
4. Peer Review In addition to the TEP described above, MetaWorks will identify up to 12 additional individuals who are expert in the topic area, to serve as peer reviewers of the draft evidence report. The profile of the peer review group will be similar to that of the TEP, and may also include representatives from major manufacturers of the medications and test interventions included in the evidence report. A copy of each draft evidence report will be sent to each peer reviewer, along with a reviewer's form to be completed and returned to MetaWorks. This form will contain a checklist of items to be assessed as well as provide room for free-form text comments. The type of commentary invited will be the type that journal reviewers are typically asked to provide, such as the scientific relevance of the topic, the appropriateness of the methods used, the quality of execution of the methods, and the presentation and interpretation of the results. Each form will show the identity of the reviewer, as well as any disclosures of conflicts of interest. The form will be pre-screened by the TEP, the TOO and CDC prior to being sent to the peer reviewers. Reviewers will be given 2 - 3 weeks to respond, after which they will be contacted. All feedback will be stored in a project folder at MetaWorks entitled "Reviewer Comments," and a statement of response to each reviewer's comments will be prepared and stored with each reviewer's comments. This response will also be returned to the reviewer. A summary of the main comments and responses will be prepared and shared with the TOO and CDC. Reviewer comments and additional analyses and text resulting from the response to reviewer critique will be incorporated into the final iteration of each evidence report.
5. Evidence Report In preparation for peer review, a draft report, in AHCPR's required format, that details the results of the literature review and evidence synthesis and including references for relevant literature and studies will be completed. Specifically, the draft report will include:
  1. description of the topic, including the specific questions that were addressed; target patient population; specification of the causal pathway underlying the review; and definition of the interventions and outcomes that were examined.
  2. brief description of the current costs of care and information on the incidence, prevalence, and burden of suffering related to the condition.
  3. description of the methodological process used, including specification of search strategies, databases, and other sources of literature used, time frame covered by the searches (beginning and end dates), study inclusion and exclusion criteria, method for assigning inclusion and exclusion criteria, method for review of evidence, criteria for rating evidence and synthesis of evidence.
  4. evidence tables for each step in the causal pathway.
  5. descriptive summary of evidence.
  6. appendices to include: data extraction form and descriptions of the analyses of the evidence.
  7. bibliography of all literature abstracted in the evidence tables or cited in the evidence report, including complete citation for each reference.
  8. summary not to exceed 10 pages that highlights key findings of the evidence synthesis.
  9. structured abstract.
  MetaWorks will submit the draft report for peer review, to the TOO, and to the designated CDC representative.
6. Final Report and Journal Article MetaWorks will review and analyze peer reviewers' comments and revise the draft report, as appropriate, within 4 weeks of sending out for peer review. MetaWorks will submit the final Evidence Report to the TOO in AHCPR's required format in print, and on disk in WP 6.1. This will include a bibliography of literature used to develop the report. At the same time, MetaWorks will also submit a draft of an article for publication in a peer-reviewed national medical journal. The article will summarize the report, including major findings, evidence tables, description of methodology, and key references. Six copies of this article will be submitted for TOO review in accordance with Section H2(a), (b), and (c) of the contract.
7. Reporting
  a. MetaWorks' Project Manager will submit to the TOO quarterly progress reports (on the 15^th^ of the month following close of each quarter) documenting progress on completing subtasks on time, and explanations for any subtasks falling behind schedule.
  b. Concurrent with submission of the final Evidence Report , MetaWorks will submit a report prepared with the CDC on how the report developed under this task order will be implemented, and how the impact of such implementation will be measured.
  c. Concurrent with submission of the final Evidence Report, MetaWorks will submit a report that identifies priorities for future research on the topics covered by this task order, as identified by preliminary work already completed as a part of Phase I and Phase II of this project and available scientific literature.
8. Dissemination As discussed in the Work Plan Phase II (rev. July 29, 1999) there are many opportunities for dissemination. Major professional societies (i.e., National Association of Epilepsy Centers, American Epilepsy Society, American College of Physicians, American Academies of Neurology, Neurosurgery and Pediatrics, etc.) as well as consumer groups will be notified of the report. A manuscript describing key aspects of the work will be submitted for publication in a peer reviewed journal, and abstracts may also be submitted for presentation at professional meetings.

#### 9.0 References

- 1.Chalmers TC, Lau J.
- Meta-analytic stimulus for changes in clinical trials. Statistical Methods in Medical Research. 1993; 2:161 - 172.

- 2.Sacks HS, Berrier J, Reitman D, Pagano D, Chalmers T.
- Meta-analyses of randomized controlled trials. New England Journal of Medicine. 1987; 316:450 - 455.

- 3.Sacks HS, Berrier J, Reitman D, Pagano D, Chalmers T.
- Meta-analyses of randomized control trials: an update of the quality and methodology. In: Bailar JC III, Mosteller F, editors. Medical Uses of Statistics. 2nd Edition. Boston: NEJM Books.1992; 427 - 442.

- 4.Cook DJ, Mulrow CD, Haynes RB.
- Systematic reviews: synthesis of best evidence for clinical decisions. Annals of Internal Medicine. 1997; 126: 376 - 380.

- 5.Mulrow CD, Oxman AD (eds).
- Cochrane Collaboration Handbook. The Cochrane Library. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997. Updated quarterly.

#### Work Plan Acceptance (Phase II - Part B Revision)

AHRQ

By: _______________________ Name: ________________________ Title: __________________________

CDC:

By: ____________________________ Name: _________________________ Title: __________________________

MetaWorks Inc.

By: ____________________________ Name: _________________________ Title: Principal Investigator, MetaWorks

LDI

By: ____________________________ Name: _________________________ Title: Principal Investigator, LDI

## Appendix 6. PATIENTS NEWLY DIAGNOSED WITH EPILEPSY DATA EXTRACTION FORM

| Extractor/date_____________
| Consensor/date____________

Study Level Characteristics Author/Year___________/_____ Location (E, NA, Other__________) Total pts_______Healthy Ss?______ Design: Observational/Interventional Retro/Pro RCT/nRCT/UCS/XS ?Open Label Ext? Yes Evidence Score = Rand___+ Blind___+ WD ____= ____ or 1 / L o E _______ = ________ Study duration: max_______(mos) mean/median_______(mos) Accrual years ________ Classification system: ILAE '81, '89, other (___________), or NR Industry sponsor (yes_______________ or no/NR) Population: Adult Peds Both Costs? (yes/no) QOL? (yes/no): if yes, tool =_______________ Intervention Location? home, hospital, office/clinic, epilepsy center, academic, other, unknown or NR Usual epilepsy care provider id'd? 1° MD, IM, Neuro, Epil MD, surgeon, radiol., other, unknown or NR Investigator id'd? 1° MD, IM, Neuro, Epil MD, surgeon, radiol, academic, other, unknown or NR Pts on study at: 1st seizure/ 1st presentation/ 1st dx/ not 1st event, but T_0_ in observation window Inclusions: NS/specified: #seizures?___ in past? ____(mos, yrs) Unprovoked? Yes/ No / NR Exclusions for 2° causes: NS / specified? Yes/No (tumor, trauma, infection, stroke, etoh/drugs, neuro, pseudo, psycho, medical, febrile, inf. spasms) 1° study objective (Dx, Mx, Tx) & text:_________________________________________.

TOTAL | | Epilepsy Patients
Patients enrolled (#)
Age (mean/median) (range)
Race (C/AA/H/A/Other - #)
Gender (M/F - #)
Family history (#)
Seizure type: # general
# partial
#absence
#other
# on AEDs at entry
# history of AED use
Epilepsy Syndrome Dx
#% with
#% with
#% with
#% with
#% with
#% with

OUTCOMES I: DIAGNOSTIC INTERVENTIONS

Diagnostic | Who ? | When? | Dx made? | DxΔ? | Costs?.
History/Physical (D11)
Blood tests (D13)
Neuropsych (D8)
LP (D9)
CT (D10)
EEG std (D5)
MRI (D6)
PET/SPECT (D7)
EEG invasive (D1)
EEG video (D2)
EEG ambulatory (D3)
EEG other (D4)

Diagnostic | Gold Std*? | Sens | Spec | "R" | PPV | NPV | 2X2 | Other.
History/Physical (D11)
Blood tests (D13)
Neuropsych (D8)
LP (D9)
CT (D10)
EEG std (D5)
MRI (D6)
PET/SPECT (D7)
EEG invasive (D1)
EEG video (D2)
EEG ambulatory (D3)
EEG other (D4)

Gold standard = epilepsy defined as_______________________________________________ _______________________________________________

Incidence new epilepsy diagnoses total n =______; n per __________ = ______

OUTCOMES II: MONITORING INTERVENTIONS

Monitoring | Who ? | When? | Where? | Frequency? | Costs?
Pharm. Exp (M4)
Blood tests (M8)
Drug levels (std) (M7)
Drug levels (soph) (M6)
EEG std (M5)
EEG invasive (M1)
EEG video (M2)
EEG ambulatory (M3)
Other (M9)

Monitoring | Δseizure fr ↓↑[image] | ΔAED AEs ↓↑[image] | Δcompliance ↓↑[image] | ΔQoL ↓↑[image] | ΔDx ↓↑[image] | ΔRx ↓↑[image]
Pharm. Exp (M4)
Blood tests (M8)
Drug levels (std) (M7)
Drug levels (soph) (M6)
EEG std (M5)
EEG invasive (M1)
EEG video (M2)
EEG ambulatory (M3)
Other (M9)

OUTCOMES III: TREATMENT INTERVENTIONS

Treatment | Who ? | When? | Where? | How long? | Costs?
No Rx (T9)
Drug studies (T2)
Drug Rx:Mono (T10)
Drug Rx: Poly (T11)
Pharm Exp. (T4)
Social services (T8)
Counsel ψ (T7)
Speech (T6)
OT/PT (T5)
Education (T3)
Surgery (T1)
Other (T12)

Treatment | Δ seizure frequency ↓↑[image] | rem/recur rate/risk ↓↑[image] | Δside effects ↓↑[image] | Δcompliance ↓↑[image] | ΔQoL ↓↑[image]
No Rx (T9)
Drug studies (T2)
Drug Rx:Mono (T10)
Drug Rx: Poly (T11)
Pharm Exp. (T4)
Social services (T8)
Counsel ψ (T7)
Speech (T6)
OT/PT (T5)
Education (T3)
Surgery (T1).
Other (T12)
Optimal outcomes defined? No/Yes: #/% unit in___duration with (code):
| Seizures.
| side effects.
| compliance.
| QoL.
| Costs.
Compliance measured by pill counts, drug levels, other____________________________________________
(rev.1-28-00)

## Appendix 7: Accepted Studies Log

### Bibliographic Record

611964 | 1 | Aikia M, Kalviainen R, Mervaala E, et al. Predictors of seizure outcome in newly diagnosed partial epilepsy: Memory performance as a prognostic factor. Epilepsy Res 1999; 37(2): 159 - 167.
591826 | 2 | Aikia M, Kalviainen R, Sivenius J, et al. Cognitive effects of oxcarbazepine and phenytoin monotherapy in newly diagnosed epilepsy: One year follow-up. Epilepsy Res 1992; 11(3): 199 - 203.
591904 | 3 | Altunbasak S, Biatmakoui F, Baytok V, et al. Serum and hair zinc levels in epileptic children taking valproic acid. Biol Trace Elem Res 1997; 58(1 - 2): 117 - 125.
591924 | 4 | Ambrosetto G, Giovanardi RP, Tassinari CA. Predictive factors of seizure frequency and duration of antiepileptic treatment in rolandic epilepsy: A retrospective study. Brain Dev 1987; 9(3): 300 - 304.
591957 | 5 | Andrewes DG, Bullen JG, Tomlinson L, et al. A comparative study of the cognitive effects of phenytoin and carbamazepine in new referrals with epilepsy. Epilepsia 1986; 27(2): 128 - 134.
587403 | 6 | Anzola GP. Predictivity of plasma prolactin levels in differentiating epilepsy from pseudoseizures: A prospective study. Epilepsia 1993; 34(6): 1044 - 1048.
592023 | 7 | Arteaga R, Herranz JL, Armijo JA. Platelet GABA-transaminase in epileptic children: Influence of epilepsy and anticonvulsants. Epilepsy Res 1993; 14(1): 73 - 85.
611997 | 8 | Arts WF, Geerts AT, Brouwer OF, et al. The early prognosis of epilepsy in childhood: The prediction of a poor outcome. The Dutch study of epilepsy in childhood. Epilepsia 1999; 40(6): 726 - 734.
  636169 | 1 | Brouwer OF, van Donselaar CA, Stroink H, et al. The Dutch study of epilepsy in childhood: Design of the study. Epilepsia 1995; 36 Suppl 3(-): S28.
  592784 | 2 | Carpay HA, Arts WF, Geerts AT, et al. Epilepsy in childhood: An audit of clinical practice. Arch Neurol 1998; 55(5): 668 - 673.
587446 | 9 | Atakli D, Sozuer D, Atay T, et al. Misdiagnosis and treatment in juvenile myoclonic epilepsy. Seizure 1998; 7(1): 63 - 66.
612042 | 10 | Berg AT, Shinnar S, Levy SR, et al. Newly diagnosed epilepsy in children: Presentation at diagnosis. Epilepsia 1999; 40(4): 445 - 452.
  612041 | 1 | Berg AT, Shinnar S, Levy SR, et al. Status epilepticus in children with newly diagnosed epilepsy. Ann Neurol 1999; 45(5): 618 - 623.
627213 | 11 | Bill PA, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in adults with previously untreated epilepsy. Epilepsy Res 1997; 27(-): 195 - 204.
592482 | 12 | Bora I, Seckin B, Zarifoglu M, et al. Risk of recurrence after first unprovoked tonic-clonic seizure in adults. J Neurol 1995; 242(3): 157 - 163.
592483 | 13 | Borah NC, Matheshwari MC. Effect of antiepileptic drugs on short-latency somatosensory evoked potentials. Acta Neurol Scand 1985; 71(4): 331 - 333.
587754 | 14 | Braathen G, Theorell K. A general hospital population of childhood epilepsy. Acta Paediatrica 1995; 84(10): 1143 - 1146.
592583 | 15 | Brodie MJ, Richens A, Yuen AW. Double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy. UK Lamotrigine/Carbamazepine Monotherapy Trial Group. Lancet 1995; 345(8948): 476 - 479.
587836 | 16 | Bye A, Lamont P, Healy L. Commencement of a pediatric EEG-video telemetry service. Clin Exp Neurol 1990; 27:83 - 88.
636175 | 17 | Callaghan N, Kenny RA, O'Neill B, et al. A prospective study between carbamazepine, phenytoin and sodium valproate as monotherapy in previously untreated and recently diagnosed patients with epilepsy. J Neurol Neurosurg Psychiatry 1985; 48(-): 639 - 44.
  592722 | 1 | Callaghan N, Garrett A, Goggin T. Withdrawal of anticonvulsant drugs in patients free of seizures for two years. A prospective study. N Engl J Med 1988; 318(15): 942 - 946.
587849 | 18 | Camfield PR, Camfield CS, Dooley JM, et al. Epilepsy after a first unprovoked seizure in childhood. Neurology 1985; 35(11): 1657 - 1660.
592741 | 19 | Camfield PR, Camfield CS, Gordon K, et al. If a first antiepileptic drug fails to control a child's epilepsy, what are the chances of success with the next drug? J Pediatr 1997; 131(6): 821 - 824.
592739 | 20 | Camfield PR, Camfield CS, Smith EC, et al. Newly treated childhood epilepsy: A prospective study of recurrences and side effects. Neurology 1985; 35(5): 722 - 725.
591753 | 21 | Canadian Study Group for Childhood Epilepsy. Clobazam has equivalent efficacy to carbamazepine and phenytoin as monotherapy for childhood eplepsy. Epilepsia 1998; 39(9): 952 - 959.
  627212 | 1 | Bawden HN, Camfield CS, Camfield PR, et al. The cognitive and behavioral effects of clobazam and standard monotherapy are comparable. Canadian Study Group for Childhood Epilepsy. Epilepsy Res 1999; 33(-): 133 - 143.
587868 | 22 | Carenini L, Bottacchi E, Camerlingo M, et al. Carbamazepine does not affect short-latency somatosensory evoked potentials: A longitudinal study in newly diagnosed epilepsy. Epilepsia 1988; 29(2): 145 - 148.
587875 | 23 | Carpay JA, de Weerd AW, Schimsheimer RJ, et al. The diagnostic yield of a second EEG after partial sleep deprivation: A prospective study in children with newly diagnosed seizures. Epilepsia 1997; 38(5): 595 - 599.
612101 | 24 | Casetta I, Granieri E, Monetti VC, et al. Early predictors of intractability in childhood epilepsy: A community-based case-control study in Copparo, Italy. Acta Neurol 1999; 99(6): 329 - 33.
  636170 | 1 | Granieri E, Rosati G, Tola R, et al. A descriptive study of epilepsy in the district of Copparo, Italy, 1964 - 1978. Epilepsia 1983; 24(-): 502 - 14.
612106 | 25 | Chadwick D. Safety and efficacy of vigabatrin and carbamazepine in newly diagnosed epilepsy: A multicenter randomised double-blind study. Vigabatrin European Monotherapy Study Group. Lancet 1999; 354(9172): 13 - 19.
592861 | 26 | Chadwick DW, Anhut H, Greiner MJ, et al. A double-blind trial of gabapentin monotherapy for newly diagnosed partial seizures. International Gabapentin Monotherapy Study Group. Neurology 1998; 51(5): 1282 - 1288.
592871 | 27 | Chandra B. First seizure in adults: To treat or not to treat? Clin Neurol Neurosurg 1992; 94 Suppl(-): S61 - 63.
587953 | 28 | Chen LS, Mitchell WG, Horton EJ, et al. Clinical utility of video-EEG monitoring. Pediatr Neurol 1995; 12(3): 220 - 224.
587955 | 29 | Chen YJ, Kang WM, So WC. Comparison of antiepileptic drugs on cognitive function in newly diagnosed epileptic children: A psychometric and neurophysiological study. Epilepsia 1996; 37(1): 81 - 86.
592938 | 30 | Christe W, Kramer G, Vigonius U, et al. A double-blind controlled clinical trial: Oxcarbazepine versus sodium valproate in adults with newly diagnosed epilepsy. Epilepsy Res 1997; 26(3): 451 - 460.
587970 | 31 | Chu NS. Long-term ambulatory cassette EEG with sphenoidal recording in complex partial seizures. Epilepsia 1991; 32(3): 351 - 357.
587996 | 32 | Cockerell OC, Johnson AL, Sander JW, et al. Prognosis of epilepsy: A review and further analysis of the first nine years of the British National General Practice Study of Epilepsy, a prospective population-based study. Epilepsia 1997; 38(1): 31 - 46.
  587992 | 1 | Cockerell OC, Johnson AL, Sander JW, et al. Mortality from epilepsy: Results from a prospective population-based study. Lancet 1994; 344(8927): 918 - 921.
  587993 | 2 | Cockerell OC, Johnson AL, Sander JWAS, et al. Remission of epilepsy: Results from the National General Practice Study of Epilepsy Lancet 1995; 346(-): 140 - 44.
  636173 | 3 | Hart YM, Sander JWAS, Johnson AL, et al. National General Practice Study of Epilepsy: Recurrence after a first seizure. Lancet 1990; 336(-): 1271 - 4.
  636174 | 4 | Hart YM, Sander JWAS, Shorvon SD. National General Practice Study of Epilepsy and Epileptic Seizures: Objectives and study methodology of the largest reported prospective cohort study of epilepsy. Neuroepidemiology 1989; 8(-): 221 - 7.
  590626 | 5 | Sander JW, Hart YM, Johnson AL, et al. National General Practice Study of Epilepsy: Newly diagnosed epileptic seizures in a general population. Lancet 1990; 336(8726): 1267 - 1271.
587245 | 33 | Collaborative Group for the Study of Epilepsy. Prognosis of epilepsy in newly referred patients: A multicenter prospective study of the effects of monotherapy on the long-term course of epilepsy. Epilepsia 1992; 33(1): 45 - 51.
  592218 | 1 | Beghi E, Tognoni G. Prognosis of epilepsy in newly referred patients: A multicenter prospective study. Collaborative Group for the Study of Epilepsy. Epilepsia 1988; 29(3): 236 - 243.
  636184 | 2 | Di Mascio R, Beghi E, Sasaneilli F, et al., and the Collaborative Group for Epidemiology of Epilepsy. Early prognosis of epilepsy. Effects of treatment in the first follow-up year. Ital J Neurol Sci 1986; 7(-): 421 - 429.
588054 | 34 | Crawford PM, Belchetz P, Davis C, et al. Growth hormone response to diazepam, clonidine and glucagon in patients with epilepsy. Epilepsy Res 1989; 3(1): 63 - 69.
588064 | 35 | Cull RE. An assessment of 24-hour ambulatory EEG/ECG monitoring in a neurology clinic. J Neurol Neurosurg Psychiatry 1985; 48(2): 107 - 110.
588082 | 36 | Dam AM, Fuglsang-Frederiksen A, Svarre-Olsen U, et al. Late-onset epilepsy: Etiologies, types of seizure, and value of clinical investigation, EEG, and computerized tomography scan. Epilepsia 1985; 26(3): 227 - 231.
588083 | 37 | Dam M, Ekberg R, Loyning Y, et al. A double-blind study comparing oxcarbazepine and carbamazepine in patients with newly diagnosed, previously untreated epilepsy. Epilepsy Res 1989; 3(1): 70 - 76.
593214 | 38 | Davidson DL, Ward NI. Abnormal aluminium, cobalt, manganese, strontium and zinc concentrations in untreated epilepsy. Epilepsy Res 1988; 2(5): 323 - 330.
593243 | 39 | De Deyn PP, Mol L, de Ridder-Vanderdeelen P, et al. An open multicentre prospective study of the effects of monotherapy with controlled-release carbamazepine on newly diagnosed generalized tonic-clonic seizures. Seizure 1994; 3(3): 235 - 238.
627217 | 40 | de Silva M, MacArdle B, McGowan M, et al. Randomized comparative monotherapy trial of phenobarbitone, phenytoin, carbamazepine, or sodium valproate for newly diagnosed childhood epilepsy. Lancet 1996; 347(-): 709 - 713.
588260 | 41 | Drake MEJ, Weate SJ, Newell SA, et al. Multiple sleep latency tests in epilepsy. Clin Electroencephalogr 1994; 25(2): 59 - 62.
588289 | 42 | Duchowny MS, Resnick TJ, Deray MJ, et al. Video EEG diagnosis of repetitive behavior in early childhood and its relationship to seizures. Pediatr Neurol 1988; 4(3): 162 - 164.
593578 | 43 | Ehrhardt P, Forsythe WI. Prognosis after grand mal seizures: A study of 187 children with three-year remissions. Dev Med Child Neurol 1989; 31(5): 633 - 639.
588367 | 44 | Elwes RD, Chesterman P, Reynolds EH. Prognosis after a first untreated tonic-clonic seizure. Lancet 1985; 2(8458): 752 - 753.
593729 | 45 | Ferrarese C, Tortorella R, Bogliun G, et al. Decreased density of lymphocyte benzodiazepine receptors in drug-resistant epileptic patients. Epilepsy Res 1997; 27(3): 181 - 185.
588476 | 46 | Foley CM, Legido A, Miles DK, et al. Diagnostic value of pediatric outpatient video-EEG. Pediatr Neurol 1995; 12(2): 120 - 124.
588486 | 47 | Forsgren L. Prospective incidence study and clinical characterization of seizures in newly referred adults. Epilepsia 1990; 31(3): 292 - 301.
588488 | 48 | Forsgren L, Bucht G, Eriksson S, et al. Incidence and clinical characterization of unprovoked seizures in adults: A prospective population-based study. Epilepsia 1996; 37(3): 224 - 229.
593813 | 49 | Forsythe I, Butler R, Berg I, et al. Cognitive impairment in new cases of epilepsy randomly assigned to carbamazepine, phenytoin and sodium valproate. Dev Med Child Neurol 1991; 33(6): 524 - 534.
  592288 | 1 | Berg I, Butler A, Ellis M, et al. Psychiatric aspects of epilepsy in childhood treated with carbamazepine, phenytoin or sodium valproate: A random trial. Dev Med Child Neurol 1993; 35(2): 149 - 157.
612212 | 50 | Frank LM, Enlow T, Holmes GL, et al. Lamictal (lamotrigine) monotherapy for typical absence seizures in children. Epilepsia 1999; 40(7): 973 - 9.
593897 | 51 | Frost JDJ, Hrachovy RA, Glaze DG, et al. Alpha rhythm slowing during initiation of carbamazepine therapy: Implications for future cognitive performance. J Clin Neurophysiol 1995; 12(1): 57 - 63.
594003 | 52 | Gastaut H, Aguglia U, Tinuper P. Benign versive or circling epilepsy with bilateral 3-CPS spike-and-wave discharges in late childhood. Ann Neurol 1986; 19(3): 301 - 303.
612236 | 53 | Gelisse P, Genton P, Bureau M, et al. Are there generalised spike waves and typical absences in benign rolandic epilepsy? Brain Dev 1999; 21(6): 390 - 396.
594065 | 54 | Gilhus NE, Matre R. Carbamazepine effects on mononuclear blood cells in epileptic patients. Acta Neurol Scand 1986; 74(3): 181 - 185.
612251 | 55 | Gobbi G, Pini A, Bertani G, et al. Prospective study of first-line vigabatrin monotherapy in childhood partial epilepsies. Epilepsy Res 1999; 35(1): 29 - 37.
588754 | 56 | Grunewald RA, Chroni E, Panayiotopoulos CP. Delayed diagnosis of juvenile myoclonic epilepsy. J Neurol Neurosurg Psychiatry 1992; 55(6): 497 - 499.
612278 | 57 | Gunduz E, Demirbilek V, Korkmaz B. Benign rolandic epilepsy: Neuropsychological findings. Seizure 1999; 8(4): 246 - 9.
588848 | 58 | Harvey AS, Berkovic SF, Wrennall JA, et al. Temporal lobe epilepsy in childhood: Clinical, EEG, and neuroimaging findings and syndrome classification in a cohort with new-onset seizures. Neurology 1997; 49(4): 960 - 968.
627216 | 59 | Hauser WA, Rich SS, Annegers JF, et al. Seizure recurrence after a first unprovoked seizure: An extended follow-up. Neurology 1990; 40(-): 1163 - 1170.
  636178 | 1 | Hauser WA, Anderson VE, Loewenson RB, et al. Seizure recurrence after a first unprovoked seizure. N Engl J Med 1982; 307(-): 522 - 28.
588857 | 60 | Hauser WA, Rich SS, Lee JR, et al. Risk of recurrent seizures after two unprovoked seizures. N Engl J Med 1998; 338(7): 429 - 434.
594494 | 61 | Heller AJ, Chesterman P, Elwes RD, et al. Phenobarbitone, phenytoin, carbamazepine, or sodium valproate for newly diagnosed adult epilepsy: A randomised comparative monotherapy trial. J Neurol Neurosurg Psychiatry 1995; 58(1): 44 - 50.
588884 | 62 | Henneman PL, DeRoos F, Lewis RJ. Determining the need for admission in patients with new-onset seizures. Ann Emerg Med 1994; 24(6): 1108 - 1114.
588932 | 63 | Hoefnagels WA, Padberg GW, Overweg J, et al. Transient loss of consciousness: The value of the history for distinguishing seizure from syncope. J Neurol 1991; 238(1): 39 - 43.
612317 | 64 | Holt-Seitz A, Wirrell EC, Sundaram MB. Seizures in the elderly: Etiology and prognosis. Can J Neuro Sci 1999; 26(2): 110 - 114.
589011 | 65 | Hughes JR, Gruener G. The success of EEG in confirming epilepsy -- Revisited. Clin Electroencephalogr 1985; 16(2): 98 - 103.
627206 | 66 | Isojarvi JI, Pakarinen AJ, Myllyla VV. Serum lipid levels during carbamazepine medication. Arch Neurol 1993; 50(-): 590 - 593.
  594809 | 1 | Isojarvi JI, Airaksinen KE, Mustonen JN, et al. Thyroid and myocardial function after replacement of carbamazepine by oxcarbazepine. Epilepsia 1995; 36(8): 810 - 816.
  627211 | 2 | Isojarvi JIT, Pakarinen AJ, Myllyla VV. Basic hematological parameters, serum gamma-glutamyl-transferase activity, and erythrocyte folate and serum vitamin B12 levels during carbamazepine and oxcarbazepine therapy. Seizure 1997; 6(-): 207 - 211.
  627207 | 3 | Isojarvi JIT, Pakarinen AJ, Myllyla VV. Thyroid function in epileptic patients treated with carbamazepine. Arch Neurol 1989; 46(-): 1175 - 1178.
589102 | 67 | Jallon P, Goumaz M, Haenggeli C, et al. Incidence of first epileptic seizures in the canton of Geneva, Switzerland. Epilepsia 1997; 38(5): 547 - 552.
589158 | 68 | Kalviainen R, Aikia M, Helkala EL, et al. Memory and attention in newly diagnosed epileptic seizure disorder. Seizure 1992; 1(4): 255 - 262.
589159 | 69 | Kalviainen R, Aikia M, Saukkonen AM, et al. Vigabatrin vs carbamazepine monotherapy in patients with newly diagnosed epilepsy. A randomized, controlled study. Arch Neurol 1995; 52(10): 989 - 996.
  587327 | 1 | Aikia M, Kalviainen R, Riekkinen PJ. Verbal learning and memory in newly diagnosed partial epilepsy. Epilepsy Res 1995; 22(2): 157 - 164.
595028 | 70 | Kalviainen R, Halonen T, Pitkanen A, et al. Amino acid levels in the cerebrospinal fluid of newly diagnosed epileptic patients: Effect of vigabatrin and carbamazepine monotherapies. J Neurochem 1993; 60(4): 1244 - 1250.
589160 | 71 | Kalviainen R, Partanen K, Aikia M, et al. MRI-based hippocampal volumetry and T2 relaxometry: Correlation to verbal memory performance in newly diagnosed epilepsy patients with left-sided temporal lobe focus. Neurology 1997; 48(1): 286 - 287.
595149 | 72 | Keranen T, Riekkinen PJ. Remission of seizures in untreated epilepsy. Br Med J 1993; 307(6902): 483.
589242 | 73 | Kilpatrick CJ, Tress BM, O'Donnell C, et al. Magnetic resonance imaging and late-onset epilepsy. Epilepsia 1991; 32(3): 358 - 364.
589259 | 74 | King MA, Newton MR, Jackson GD, et al. Epileptology of the first-seizure presentation: A clinical, electroencephalographic, and magnetic resonance imaging study of 300 consecutive patients. Lancet 1998; 352(9133): 1007 - 1011.
  612387 | 1 | King MA, Newton MR, Berkovic SF. Benign partial seizures of adolescence. Epilepsia 1999; 40(9): 1244 - 1247.
595311 | 75 | Konishi T, Naganuma Y, Hongou K, et al. Effects of antiepileptic drugs on EEG background activity in children with epilepsy: Initial phase of therapy. Clin Electroencephalogr 1995; 26(2): 113 - 119.
595539 | 76 | Larkin JG, McKee PJ, Brodie MJ. Rapid tolerance to acute psychomotor impairment with carbamazepine in epileptic patients. Br J Clin Pharmacol 1992; 33(1): 111 - 114.
589484 | 77 | Lee SI. Nonconvulsive status epilepticus. Ictal confusion in later life. Arch Neurol 1985; 42(8): 778 - 781.
589617 | 78 | Luhdorf K, Jensen LK, Plesner AM. Epilepsy in the elderly: Prognosis. Acta Neurol Scand 1986; 74(5): 409 - 415.
595966 | 79 | Mandelbaum DE, Burack GD. The effect of seizure type and medication on cognitive and behavioral functioning in children with idiopathic epilepsy. Dev Med Child Neurol 1997; 39(11): 731 - 735.
595993 | 80 | Marciani MG, Maschio MC, Spanedda F, et al. Sodium valproate and mental processes in newly referred epileptic patients. A computerized EEG study. Neuropsychobiology 1995; 31(4): 210 - 215.
589702 | 81 | Martinovic Z, Jovic N. Seizure recurrence after a first generalized tonic-clonic seizure, in children, adolescents and young adults. Seizure 1997; 6(6): 461 - 465.
636181 | 82 | Mattson RH, Cramer JA, Collins JF for the Department of Veterans Affairs Epilepsy Cooperative Study Group. A comparison of valproate with carbamazepine for the treatment of complex partial seizres and secondarily generalized tonic-clonic seizures in adults. New Eng J Med 1992; 327(11): 765 - 71.
  636183 | 1 | Prevey ML, Delaney RC, Cramer JA, et al. Effect of valproate on cognitive functioning. Arch Neurol 1998; 53(-): 1008 - 16.
  597177 | 2 | Prevey ML, Delaney RC, Cramer JA, et al. Complex partial and secondarily generalized seizure patients: Cognitive functioning prior to treatment with antiepileptic medication. VA Epilepsy Cooperative Study 264 Group. Epilepsy Res 1998; 30(1): 1 - 9.
596197 | 83 | McNelis A, Musick B, Austin J, et al. Psychosocial care needs of children with new-onset seizures. J Neurosci Nurs 1998; 30(3): 161 - 165.
  636171 | 1 | Austin J, Dunn D, Huster G, et al. Development of scales to measure psychosocial care needs of children with seizures and their parents. J Neurosci Nurs 1998; 30(3): 155 - 60.
  636172 | 2 | Austin JK. Concerns and fears of children with seizures. Clin Nurs Practice Epilepsy 1993; 1(-): 4 - 6.
  598019 | 3 | Shore C, Austin J, Musick B, et al. Psychosocial care needs of parents of children with new-onset seizures. J Neurosci Nurs 1998; 30(3): 169 - 174.
596268 | 84 | Mervaala E, Keranen T, Tiihonen P, et al. The effects of carbamazepine and sodium valproate on SEPs and BAEPs. Electroencephalogr Clin Neurophysiol 1987; 68(6): 475 - 478.
589876 | 85 | Mohan KK, Markand ON, Salanova V. Diagnostic utility of video EEG monitoring in paroxysmal events. Acta Neurol Scand 1996; 94(5): 320 - 325.
596518 | 86 | Musicco M, Beghi E, Solari A, et al. Treatment of first tonic-clonic seizure does not improve the prognosis of epilepsy. First Seizure Trial Group. Neurology 1997; 49(4): 991 - 998.
  636180 | 1 | Musicco M and the First Seizure Trial Group. Randomized clinical trial on the efficacy of antiepileptic drugs in reducing the risk of relapse after a first unprovoked tonic-clonic seizure. Neurology 1993; 43(-): 478 - 83.
590005 | 87 | Neufeld MY, Treves TA, Chistik V, et al. Sequential serum creatine kinase determination differentiates vaso-vagal syncope from generalized tonic-clonic seizures. Acta Neurol Scand 1997; 95(3): 137 - 139.
596672 | 88 | O'Dougherty M, Wright FS, Cox S, et al. Carbamazepine plasma concentration. Relationship to cognitive impairment. Arch Neurol 1987; 44(8): 863 - 867.
596738 | 89 | Oka E, Yamatogi Y, Ohtsuka Y, et al. Clinical course and prognosis of childhood epilepsy. Acta Paediatr Jpn 1989; 31(3): 259 - 266.
590131 | 90 | Oldani A, Zucconi M, Smirne S, et al. The neurophysiological evaluation of nocturnal frontal lobe epilepsy. Seizure 1998; 7(4): 317 - 320.
590139 | 91 | Oller-Daurella L, Oller LF. Influence of the 'lost time' on the outcome of epilepsy. Eur Neurol 1991; 31(3): 175 - 177.
590212 | 92 | Panayiotopoulos CP, Chroni E, Daskalopoulos C, et al. Typical absence seizures in adults: Clinical, EEG, video-EEG findings and diagnostic/syndromic considerations. J Neurol Neurosurg Psychiatry 1992; 55(11): 1002 - 1008.
590210 | 93 | Panayiotopoulos CP, Tahan R, Obeid T. Juvenile myoclonic epilepsy: Factors of error involved in the diagnosis and treatment. Epilepsia 1991; 32(5): 672 - 676.
596953 | 94 | Pedersen SB, Petersen KA. Juvenile myoclonic epilepsy: Clinical and EEG features. Acta Neurol Scand 1998; 97(3): 160 - 163.
596990 | 95 | Penry JK, Dean JC, Riela AR. Juvenile myoclonic epilepsy: Long-term response to therapy. Epilepsia 1989; 30 Suppl 4(-): S19 - 23.
590390 | 96 | Pulliainen V, Jokelainen M. Effects of phenytoin and carbamazepine on cognitive functions in newly diagnosed epileptic patients. Acta Neurol Scand 1994; 89(2): 81 - 86.
  597201 | 1 | Pulliainen V, Jokelainen M. Comparing the cognitive effects of phenytoin and carbamazepine in long-term monotherapy: A two-year follow-up. Epilepsia 1995; 36(12): 1195 - 1202.
590459 | 97 | Reutens DC, Berkovic SF. Idiopathic generalized epilepsy of adolescence: Are the syndromes clinically distinct? Neurology 1995; 45(8): 1469 - 1476.
590479 | 98 | Richens A, Davidson DL, Cartlidge NE, et al. A multicenter comparative trial of sodium valproate and carbamazepine in adult onset epilepsy. Adult EPITEG Collaborative Group. J Neurol Neurosurg Psychiatry 1994; 57(6): 682 - 687.
597434 | 99 | Ring HA, Heller AJ, Marshall WJ, et al. Plasma uric acid in patients receiving anticonvulsant monotherapy. Epilepsy Res 1991; 8(3): 241 - 244.
590499 | 100 | Roberts R, Fitch P. Monitoring at the National Hospital, Queen Square, London. Electroencephalogr Clin Neurophysiol 1985; 37 Suppl(-): 423 - 436.
597708 | 101 | Sannita WG, Gervasio L, Zagnoni P. Quantitative EEG effects and plasma concentration of sodium valproate: Acute and long-term administration to epileptic patients. Neuropsychobiology 1989; 22(4): 231 - 235.
590648 | 102 | Saukkonen A, Kalviainen R, Partanen K, et al. Do seizures cause neuronal damage? A MRI study in newly diagnosed and chronic epilepsy. Neuroreport 1994; 6(1): 219 - 223.
590782 | 103 | Sharpe C, Buchanan N. Juvenile myoclonic epilepsy: Diagnosis, management and outcome. Med J Aust 1995; 162(3): 133 - 134.
612755 | 104 | Shihabuddin B, Abou-Khalil B, Fakhoury T. The value of combined ambulatory cassette-eeg and video monitoring in the differential diagnosis of intractable seizures. Clin Neurophysiol 1999; 110(8): 1452 - 1457.
627231 | 105 | Shinnar S, Berg AT, Moshe SL, et al. The risk of seizure recurrence after a first unprovoked afebrile seizure in childhood: An extended follow-up. Pediatrics 1996; 98(2): 216 - 225.
  590811 | 1 | Shinnar S, Berg AT, Moshe SL, et al. Risk of seizure recurrence following a first unprovoked seizure in childhood: A prospective study. Pediatrics 1990; 85(6): 1076 - 1085.
  590814 | 2 | Shinnar S, Kang H, Berg AT, et al. EEG abnormalities in children with a first unprovoked seizure. Epilepsia 1994; 35(3): 471 - 476.
598126 | 106 | Smith DB, Mattson RH, Cramer JA, et al. Results of a nationwide Veterans Administration Cooperative Study comparing the efficacy and toxicity of carbamazepine, phenobarbital, phenytoin, and primidone. Epilepsia 1987; 28 Suppl 3(-): S50 - 58.
  636182 | 1 | Cramer JA, Smith DB, Mattson RH, et al. A method of quantification for the evaluation of antiepileptic drug therapy. The VA Epilepsy Cooperative Study Group. Neurology 1983; 33 Suppl 1(-): 26 - 37.
590932 | 107 | Sperling MR, Engel JJ. Electroencephalographic recording from the temporal lobes: A comparison of ear, anterior temporal, and nasopharyngeal electrodes. Ann Neurol 1985; 17(5): 510 - 513.
598287 | 108 | Stefan H, Plouin P, Fichsel H, et al. Progabide for previously untreated absence epilepsy. Epilepsy Res 1988; 2(2): 132 - 136.
612782 | 109 | Steiner TJ, Dellaportas CL, Findley LJ, et al. Lamotrigine monotherapy in newly diagnosed untreated epilepsy: A double-blind comparison with phenytoin. Epilepsia 1999; 40(5): 601 - 607.
591077 | 110 | Tanganelli P, Regesta G. Vigabatrin vs. carbamazepine monotherapy in newly diagnosed focal epilepsy: A randomized response conditional cross-over study. Epilepsy Res 1996; 25(3): 257 - 262.
591202 | 111 | Trudeau V, Myers S, LaMoreaux L, et al. Gabapentin in naive childhood absence epilepsy: Results from two double-blind, placebo-controlled, multicenter studies. J Child Neurol 1996; 11(6): 470 - 475.
598756 | 112 | Turnbull DM, Howel D, Rawlins MD, et al. Which drug for the adult epileptic patient: Phenytoin or valproate? Br Med J 1985; 290(6471): 815 - 819.
598827 | 113 | van Donselaar CA, Geerts AT, Schimsheimer RJ. Idiopathic first seizure in adult life: Who should be treated? Br Med J 1991; 302(6777): 620 - 623.
591276 | 114 | Van Paesschen W, Duncan JS, Connelly A. A comparison of the neuropathological effects of vigabatrin and carbamazepine in patients with newly diagnosed localization-related epilepsy using MR-based cerebral T2 relaxation time measurements. Epilepsy Res 1998; 29(2): 155 - 160.
636179 | 115 | Van Paesschen W, Duncan JS, Stevens JM, et al. Etiology and early prognosis of newly diagnosed partial seizures in adults: A quantitative hippocampal MRI study. Neurology 1997; 49(-): 753 - 57.
  591277 | 1 | Van Paesschen W, Duncan JS, Stevens JM, et al. Longitudinal quantitative hippocampal magnetic resonance imaging study of adults with newly diagnosed partial seizures: One-year follow-up results. Epilepsia 1998; 39(6): 633 - 639.
591320 | 116 | Verity CM, Hosking G, Easter DJ. A multicenter comparative trial of sodium valproate and carbamazepine in paediatric epilepsy. The Paediatric EPITEG Collaborative Group. Dev Med Child Neurol 1995; 37(2): 97 - 108.
591380 | 117 | Walsh JC, Vignaendra V, Burrows S, et al. The application of prolonged electroencephalographic monitoring and video recording to the diagnosis of epilepsy. Med J Aust 1986; 144(8): 401 - 404.
591464 | 118 | Williams J, Bates S, Griebel ML, et al. Does short-term antiepileptic drug treatment in children result in cognitive or behavioral changes? Epilepsia 1998; 39(10): 1064 - 1069.
599227 | 119 | Wolf P. Non-medical treatment of first epileptic seizures in adolescence and adulthood. Seizure 1995; 4(2): 87 - 94.
599410 | 120 | Zamponi N, Cardinali C. Open comparative long-term study of vigabatrin vs. carbamazepine in newly diagnosed partial seizures in children. Arch Neurol 1999; 56(5): 605 - 607.

## Appendix 8: Rejected Studies Log

### Citation

Rejection | Foreign Language
1 | Dam M, Holzer KI. Development of epilepsy after the first seizure. Ugeskr Laeger 1988; 150(44): 2632 - 35.

Rejection | Less than 10 patients total sample size
1 | Borkowski WJJ, Ellington RJ, Sverdrup EK. Effect of sleep deprivation on the EEG of learning-impaired children with absence seizures. Clin Electroencephalogr 1992; 23(2): 62 - 64.
2 | Drislane FW, Blum AS, Schomer DL. Focal status epilepticus: Clinical features and significance of different EEG patterns. Epilepsia 1999; 40(9): 1254 - 60.
3 | Gigli GL, Maschio M, Diomedi M, et al. Cognitive performance in newly referred patients with temporal lobe epilepsy: Comparison with normal subjects in basal condition and after treatment with carbamazepine. Int J Neurosci 1996; 88(1 - 2): 97 - 107.
4 | Kivity S, Lerman P. Stormy onset with prolonged loss of consciousness in benign childhood epilepsy with occipital paroxysms. J Neurol Neurosurg Psychiatry 1992; 55(1): 45 - 8.
5 | Okino S. Familial benign myoclonus epilepsy of adult onset: A previously unrecognized myoclonic disorder. J Neurol Sci 1997; 145(1): 113 - 18.
6 | Panayiotopoulos CP. Elementary visual hallucinations, blindness, and headache in idiopathic occipital epilepsy: Differentiation from migraine. J Neurol Neurosurg Psychiatry 1999; 66(4): 536 - 40.
7 | Panayiotopoulos CP. Extraoccipital benign childhood partial seizures with ictal vomiting and excellent prognosis. J Neurol Neurosurg Psychiatry 1999; 66(1): 82 - 85.
8 | Shuper A, Mimouni M. Problems of differentiation between epilepsy and non-epileptic paroxysmal events in the first year of life. Arch Dis Child 1995; 73(4): 342 - 44.
9 | Sutherling W, Crandall P, Levesque M, et al. Physical interpretation of frontal lobe seizures. The dipole approximation and sensorimotor cortex. Adv Neurol 1992; 57(-): 339 - 47.
10 | Wang PJ, Lee WT, Hwu WL, et al. The controversy regarding diagnostic criteria for early myoclonic encephalopathy. Brain Dev 1998; 20(7): 530 - 35.

Rejection | Major data inconsistencies in report
1 | Matsushita M, Nakamura K, Usuki T, et al. Retrospective study of single unprovoked seizure. Jpn J Psychiatry Neurol 1993; 47(2): 356 - 57.

Refer to Table

Rejection | No Outcomes of Interest
1 | Benninger C, Matthis P, Scheffner D. Spectral analysis of the EEG in children during the introduction of antiepileptic therapy with valproic acid. Neuropsychobiology 1985; 13(1 - 2): 93 - 96.

Rejection | No outcomes reported
1 | Liwen W, Scheuer M. A diagnostic practice study using international classification of epilepsies and epileptic syndromes in 302 cases. Chin Med Sci J 1995; 10(4): 204 - 09.

Rejection | No population of interest
1 | Adam C, Baulac M, Saint-Hilaire JM, et al. Value of magnetic resonance imaging-based measurements of hippocampal formations in patients with partial epilepsy. Arch Neurol 1994; 51(2): 130 - 38.
2 | Adamson TA, Fasoranti B, Adamson I. Blood tryptophan and ATPase in psychosis of epilepsy. West Afr J Med 1991; 10(1): 420 - 25.
3 | Agathonikou A, Panayiotopoulos CP, Giannakodimos S, et al. Typical absence status in adults: Diagnostic and syndromic considerations. Epilepsia 1998; 39(12): 1265 - 76.
4 | Al-Qudah AA, Abu-Sheik S, Tamimi AP. Diagnostic value of short duration outpatient video electroencephalographic monitoring. Ped Neurol 1999; 21(3): 622 - 25.
5 | Aliberti V, Grunewald RA, Panayiotopoulos CP, et al. Focal electroencephalographic abnormalities in juvenile myoclonic epilepsy. Epilepsia 1994; 35(2): 297 - 301.
6 | Alper K, Devinsky O, Perrine K, et al. Dissociation in epilepsy and conversion nonepileptic seizures. Epilepsia 1997; 38(9): 991 - 97.
7 | Alving J. Serum prolactin levels are elevated also after pseudo-epileptic seizures. Seizure 1998; 7(2): 85 - 9.
8 | Ammirati F, Colivicchi F, Di Battista G, et al. Variable cerebral dysfunction during tilt induced vasovagal syncope. PACE 1998; 21(11 Pt. 2): 2420 - 25.
9 | Ammirati F, Colivicchi F, Di Battista G, et al. Electroencephalographic correlates of vasovagal syncope induced by head-up tilt testing. Stroke 1998; 29(11): 2347 - 51.
10 | Anderson DW, Schoenberg BS, Haerer AF. Prevalence surveys of neurologic disorders: Methodologic implications of the Copiah County Study. J Clin Epidemiol 1988; 41(4): 339 - 45.
11 | Angeleri F, Majkowski J, Cacchio G, et al. Posttraumatic epilepsy risk factors: one-year prospective study after head injury. Epilepsia 1999; 40(9): 1222 - 30.
12 | Annegers JF, Hauser WA, Shirts SB, et al. Factors prognostic of unprovoked seizures after febrile convulsions. N Engl J Med 1987; 316(9): 493 - 98.
13 | Arboix A, Garcia-Eroles L, Massons JB, et al. Predictive factors of early seizures after acute cerebrovascular disease. Stroke 1997; 28(8): 1590 - 94.
14 | Armstrong KK, Sahgal V, Bloch R, et al. Rehabilitation outcomes in patients with posttraumatic epilepsy. Arch Phys Med Rehabil 1990; 71(2): 156 - 60.
15 | Asikainen I, Kaste M, Sarna S. Early and late posttraumatic seizures in traumatic brain injury rehabilitation patients: Brain injury factors causing late seizures and influence of seizures on long-term outcome. Epilepsia 1999; 40(5): 584 - 89.
16 | Astradsson A, Olafsson E, Ludvigsson P, et al. Rolandic epilepsy: An incidence study in Iceland. Epilepsia 1998; 39(8): 884 - 86.
17 | Bagdorf R, Lee SI. Midline spikes: Is it another benign EEG pattern of childhood? Epilepsia 1993; 34(2): 271 - 74.
18 | Bartolomei F, Roger J, Bureau M, et al. Prognostic factors for childhood and juvenile absence epilepsies. Eur Neurol 1997; 37(-): 169 - 75.
19 | Bazil CW, Kothari M, Luciano D, et al. Provocation of nonepileptic seizures by suggestion in a general seizure population. Epilepsia 1994; 35(4): 768 - 70.
20 | Beenen LM, Lindeboom J, Trenite DN, et al. Comparative double blind clinical trial of phenytoin and sodium valproate as anticonvulsant prophylaxis after craniotomy: Efficacy, tolerability, and cognitive effects. J Neurol Neurosurg Psych 1999; 67(4): 474 - 80.
21 | Beirne M, Acomb B, Appleton R. Clinicians' vs. technicians' history when obtaining an EEG. Seizure 1996; 5(4): 279 - 81.
22 | Bell AH, McClure BG, Hicks EM. Power spectral analysis of the EEG of term infants following birth asphyxia. Dev Med Child Neurol 1990; 32(11): 990 - 98.
23 | Bell WL, Park YD, Thompson EA, et al. Ictal cognitive assessment of partial seizures and pseudoseizures. Arch Neurol 1998; 55(11): 1456 - 59.
24 | Benbadis SR. Observations on the misdiagnosis of generalized epilepsy as partial epilepsy: Causes and consequences. Seizure 1999; 8(3): 140 - 45.
25 | Benbadis SR, Wolgamuth BR, Goren H, et al. Value of tongue biting in the diagnosis of seizures. Arch Intern Med 1995; 155(21): 2346 - 49.
26 | Beran RG, Plunkett MJ, Holland GJ. Interface of epilepsy and sleep disorders. Seizure 1999; 8(2): 97 - 102.
27 | Berkhoff M, Briellmann RS, Radanov BP, et al. Developmental background and outcome in patients with nonepileptic versus epileptic seizures: A controlled study. Epilepsia 1998; 39(5): 463 - 69.
28 | Beun AM, van Emde B, Dekker E. Sharp transients in the sleep EEG of healthy adults: A possible pitfall in the diagnostic assessment of seizure disorders. Electroencephalogr Clin Neurophysiol 1998; 106(1): 44 - 51.
29 | Bhatia M, Sinha PK, Jain S, et al. Usefulness of short-term video EEG recording with saline induction in pseudoseizures. Acta Neurol Scand 1997; 95(6): 363 - 66.
30 | Bidzinski J, Marchel A, Sherif A. Risk of epilepsy after aneurysm operations. Acta Neurochir 1992; 119(1 - 4): 49 - 52.
31 | Bladin PF. Adult Lennox Gastaut syndrome: Features and diagnostic problems. Clin Exp Neurol 1985; 21(-): 93 - 104.
32 | Branford D, Bhaumik S, Duncan F. Epilepsy in adults with learning disabilities. Seizure 1998; 7(6): 473 - 7.
33 | Bridgers SL. Ambulatory cassette electroencephalography of psychiatric patients. Arch Neurol 1988; 45(1): 71 - 74.
34 | Brodie MJ, McPhail E, Macphee GJ, et al. Psychomotor impairment and anticonvulsant therapy in adult epileptic patients. Eur J Clin Pharmacol 1987; 31(6): 655 - 60.
35 | Buchanan N, Snars J. Pseudoseizures (non epileptic attack disorder) -- Clinical management and outcome in 50 patients. Seizure 1993; 2(2): 141 - 46.
36 | Burgess RJ, Drake MEJ, Paulson GW. Interictal EEG prediction of response to antiepileptic drug monotherapy. Clin Electroencephalogr 1985; 16(3): 131 - 35.
37 | Chabrol B, Decarie JC, Fortin G. The role of cranial MRI in identifying patients suffering from child abuse and presenting with unexplained neurological findings. Child Abuse Negl 1999; 23(3): 217 - 28.
38 | Chee MW, Morris HH, Antar MA, et al. Presurgical evaluation of temporal lobe epilepsy using interictal temporal spikes and positron emission tomography. Arch Neurol 1993; 50(1): 45 - 48.
39 | Clancy RR, Legido A. Postnatal epilepsy after EEG-confirmed neonatal seizures. Epilepsia 1991; 32(1): 69 - 76.
40 | Conlon P, Trimble MR, Rogers D. A study of epileptic psychosis using magnetic resonance imaging. Br J Psychiatry 1990; 156(-): 231 - 35.
41 | Connell J, Oozeer R, de Vries L, et al. Clinical and EEG response to anticonvulsants in neonatal seizures. Arch Dis Child 1989; 64(4): 459 - 64.
42 | Cooper WO, Federspiel CF, Griffin MR, et al. New use of anticonvulsant medications among children enrolled in the Tennessee Medicaid Program. Arch Pediatr Adolesc Med 1997; 151(12): 1242 - 46.
43 | Coppola G, Plouin P, Chiron C, et al. Migrating partial seizures in infancy: A malignant disorder with developmental arrest. Epilepsia 1995; 36(10): 1017 - 24.
44 | Cusmai R, Chiron C, Curatolo P, et al. Topographic comparative study of magnetic resonance imaging and electroencephalography in 34 children with tuberous sclerosis. Epilepsia 1990; 31(6): 747 - 55.
45 | Czochanska J, Langner-Tyszka B, Losiowski Z, et al. Children who develop epilepsy in the first year of life: A prospective study. Dev Med Child Neurol 1994; 36(4): 345 - 50.
46 | Davis TL, Freemon FR. Electroencephalography should not be routine in the evaluation of syncope in adults. Arch Intern Med 1990; 150(10): 2027 - 29.
47 | de Albuquerque M, de Campos CJ. Epilepsy and anxiety. Arq Neuropsiquiatr 1993; 51(3): 313 - 18.
48 | de Feo MR, Mecarelli O, Ricci G, et al. The utility of ambulatory EEG monitoring in typical absence seizures. Brain Dev 1991; 13(4): 223 - 7.
49 | De Negri M, Cremonte M, Veneselli E, et al. Secondary generalized epilepsy in childhood: EEG patterns and correlation with responsiveness to benzodiazepines or ACTH (preliminary note). Brain Dev 1988; 10(6): 375 - 81.
50 | De Negri M, Gaggero R, Baglietto MG. Computed EEG topography (CET) and childhood epilepsy: Two years experience. Brain Dev 1990; 12(2): 253 - 56.
51 | de Weerd AW, Arts WF. Significance of centro-temporal spikes on the EEG. Acta Neurol Scand 1993; 87(6): 429 - 33.
52 | Degen R, Degen HE, Roth C. Some genetic aspects of idiopathic and symptomatic absence seizures: Waking and sleep EEGs in siblings. Epilepsia 1990; 31(6): 784 - 94.
53 | Dericioglu N, Saygi S, Ciger A. The value of provocation methods in patients suspected of having non-epileptic seizures. Seizure 1999; 8(3): 152 - 6.
54 | Devinsky O, Gordon E. Epileptic seizures progressing into nonepileptic conversion seizures. Neurology 1998; 51(5): 1293 - 96.
55 | Dias MS, Carnevale F, Li V. Immediate posttraumatic seizures: is routine hospitalization necessary? Pediatr 1999; 30(5): 232 - 8.
56 | Donat JF, Wright FS. Seizures in series: Similarities between seizures of the west and Lennox-Gastaut syndromes. Epilepsia 1991; 32(4): 504 - 9.
57 | Donat JF, Wright FS. Episodic symptoms mistaken for seizures in the neurologically impaired child. Neurology 1990; 40(1): 156 - 57.
58 | Donovan PJ, Cline D. Phenytoin administration by constant intravenous infusion: Selective rates of administration. Ann Emerg Med 1991; 20(2): 139 - 42.
59 | Dooley JM, Camfield PR, Camfield CS, et al. Once-daily ethosuximide in the treatment of absence epilepsy. Pediatr Neurol 1990; 6(1): 38 - 39.
60 | Doose H. Absence epilepsy of early childhood -- Genetic aspects. Eur J Pediatr 1994; 153(-): 372 - 77.
61 | Drake MEJ. Saline activation of pseudoepileptic seizures: Clinical EEG and neuropsychiatric observations. Clin Electroencephalogr 1985; 16(3): 171 - 76.
62 | Eadie MJ. The I.L.A.E. classification of the epilepsies applied retrospectively to 1902 patients. Epilepsy Res 1996; 25(3): 277 - 84.
63 | Eadie MJ. Epileptic seizures in 1902 patients: A perspective from a consultant neurological practice (1961 - 1991). Epilepsy Res 1994; 17(1): 55 - 79.
64 | Ettinger AB, Weisbrot DM, Nolan E, et al. Postictal symptoms help distinguish patients with epileptic seizures from those with non-epileptic seizures. Seizure 1999; 8(3): 149 - 51.
65 | Fisher RS, Chan DW, Bare M, et al. Capillary prolactin measurement for diagnosis of seizures. Ann Neurol 1991; 29(2): 187 - 90.
66 | Fisher RS, Niedermeyer E. Depth EEG studies in the Lennox-Gastaut syndrome. Clin Electroencephalogr 1987; 18(4): 191 - 200.
67 | Frost JDJ, Hrachovy RA, Glaze DG. Spike morphology in childhood focal epilepsy: Relationship to syndromic classification. Epilepsia 1992; 33(3): 531 - 36.
68 | Fylan F, Edson AS, Harding GF. Clinical significance of EEG abnormalities during photic stimulation in patients with photosensitive epilepsy. Epilepsia 1999; 40(3): 370 - 2.
69 | Fylan F, Harding GF, Edson AS, et al. Mechanisms of video-game epilepsy. Epilepsia 1999; 40 Suppl 4(-): 28 - 30.
70 | Galletti F, Rinna A, Acquafondata C. An insight into children's and adolescents' experience of seizures and epilepsy. Seizure 1998; 7(4): 309 - 316.
71 | Ganji S, Hellman CD. Tuberous sclerosis: Long-term follow-up and longitudinal electroencephalographic study. Clin Electroencephalogr 1985; 16(4): 219 - 224.
72 | Garcia HH, Gilman R, Martinez M, et al. Cysticercosis as a major cause of epilepsy in Peru. The Cysticercosis Working Group in Peru (CWG). Lancet 1993; 341(8839): 197 - 200.
73 | Gates JR, Ramani V, Whalen S, et al. Ictal characteristics of pseudoseizures. Arch Neurol 1985; 42(12): 1183 - 87.
74 | Gerard G, Shabas D, Rossi D. MRI in epilepsy. Comput Radiol 1988; 11(5/6): 223 - 27.
75 | Gillham RA, Williams N, Wiedmann K, et al. Concentration-effect relationships with carbamazepine and its epoxide on psychomotor and cognitive function in epileptic patients. J Neurol Neurosurg Psychiatry 1988; 51(7): 929 - 33.
76 | Glauser TA, Clancy RR. Adequacy of routine EEG examinations in neonates with clinically suspected seizures. J Child Neurol 1992; 7(2): 215 - 20.
77 | Goodin DS, Aminoff MJ, Laxer KD. Detection of epileptiform activity by different noninvasive EEG methods in complex partial epilepsy. Ann Neurol 1990; 27(3): 330 - 34.
78 | Gotman J. Automatic seizure detection: Improvements and evaluation. Electroencephalogr Clin Neurophysiol 1990; 76(4): 317 - 24.
79 | Grote CL, Van Slyke P, Hoeppner, JB. Language outcome following multiple subpial transection for Landau-Kleffner syndrome. Brain 1999; 122(Pt. 3): 561 - 66.
80 | Gruber R, Bubl R, Fruttiger V. Anticonvulsive prophylaxis after juvenile craniocerebral injuries: A retrospective evaluation. Z Kinderchir 1985; 40(4): 199 - 202.
81 | Guerreiro C, Cendes F, Li LM, et al. Clinical patterns of patients with temporal lobe epilepsy and pure amygdalar atrophy. Epilepsia 1999; 40(4): 453 - 61.
82 | Gupta SK, Satishchandra P, Venkatesh A, et al. Prognosis of single unprovoked seizure. J Assoc Physicians India 1993; 41(11): 709 - 10.
83 | Gurney JG, Mueller BA, Preston-Martin S, et al. A study of pediatric brain tumors and their association with epilepsy and anticonvulsant use. Neuroepidemiology 1997; 16(5): 248 - 55.
84 | Hakeem VF, Wallace SJ. EEG monitoring of therapy for neonatal seizures. Dev Med Child Neurol 1990; 32(10): 858 - 64.
85 | Hamer HM, Najm I, Mohamed A, et al. Interictal epileptiform discharges in temporal lobe epilepsy due to hippocampal sclerosis versus medial temporal lobe tumors. Epilepsia 1999; 40(9): 1261 - 68.
86 | Harvey AS, Bowe JM, Hopkins IJ, et al. Ictal 99mTc-HMPAO single photon emission computed tomography in children with temporal lobe epilepsy. Epilepsia 1993; 34(5): 869 - 77.
87 | Haslam RH, Freigang B. Cough syncope mimicking epilepsy in asthmatic children. Can J Neurol Sci 1985; 12(1): 45 - 47.
88 | Haupt C, Zarbock G, Schulte FJ. Tumors of the cerebral hemispheres in children and adolescents. Results of treatment, residual syndromes and focal epilepsy. Klin Padiatr 1995; 207(2): 73 - 80.
89 | Helmstaedter C, Wagner G, Elger CE. Differential effects of first antiepileptic drug application on cognition in lesional and non-lesional patients with epilepsy. Seizure 1993; 2(2): 125 - 30.
90 | Herzog AG. Psychoneuroendocrine aspects of temporolimbic epilepsy. Part II: Epilepsy and reproductive steroids. Psychosomatics 1999; 40(2): 102 - 08.
91 | Holland RW, Marx JA, Earnest MP, et al. Grand mal seizures temporally related to cocaine use: Clinical and diagnostic features. Ann Emerg Med 1992; 21(7): 772 - 76.
92 | Holopainen IE, Valtonen ME, Komu ME, et al. Proton spectroscopy in children with epilepsy and febrile convulsions. Pediatr Neurol 1998; 19(2): 93 - 99.
93 | Hongo K, Naganuma Y, Murakami M, et al. Development of EEG background activity in children with benign partial epilepsy. J Psychiatry Neurol 1990; 44(2): 367 - 68.
94 | Hornig CR, Buttner T, Hufnagel A, et al. Epileptic seizures following ischaemic cerebral infarction. Clinical picture, CT findings and prognosis. Eur Arch Psychiatry Neurol Sci 1990; 239(6): 379 - 83.
95 | Howell SJ, Owen L, Chadwick DW. Pseudostatus epilepticus. Q J Med 1989; 71(266): 507 - 19.
96 | Hrachovy RA, Frost JDJ, Glaze DG. Coupling of focal electrical seizure discharges with infantile spasms: Incidence during long-term monitoring in newly diagnosed patients. J Clin Neurophysiol 1994; 11(4): 461 - 64.
97 | Hughes J, Devinsky O, Feldmann E, et al. Premonitory symptoms in epilepsy. Seizure 1993; 2(3): 201 - 03.
98 | Husain AM, Mebust KA, Radtke RA. Generalized periodic epileptiform discharges: Etiologies, relationship to status epilepticus, and prognosis. J Clin Neurophysiol 1999; 16(1): 51 - 8.
99 | Jabbari B, Gunderson CH, Wippold F, et al. Magnetic Resonance Imaging in Partial Complex Epilepsy. Arch Neurol 1986; 43(-): 869 - 72.
100 | Jain S, Padma MV, Kanga U, et al. Family studies and human leukocyte antigen class II typing in Indian probands with seizures in association with single small enhancing computed tomography lesions. Epilepsia 1999; 40(2): 232 - 38.
101 | Jedrzejczak J, Owczarek K, Majkowski J. Psychogenic pseudoepileptic seizures: Clinical and electroencephalogram (EEG) video-tape recordings. Eur J Neurol 1999; 6(4): 473 - 9.
102 | Kanner AM, Morris HH, Luders H, et al. Supplementary motor seizures mimicking pseudoseizures: Some clinical differences. Neurology 1990; 40(9): 1404 - 07.
103 | Kasai K, Onuma T, Kato M, et al. Differences in evoked potential characteristics between DRPLA patients and patients with progressive myoclonic epilepsy: Preliminary findings indicating usefulness for differential diagnosis. Epilepsy Res 1999; 37(1): 3 - 11.
104 | Knudsen FU. Effective short-term diazepam prophylaxis in febrile convulsions. J Pediatr 1985; 106(3): 487 - 90.
105 | Kolmel HW. Complex visual hallucinations in the hemianopic field. J Neurol Neurosurg Psychiatry 1985; 48(1): 29 - 38.
106 | Koyama A, Matsui T, Sugisawa T. Febrile convulsions in northern Japan: A quantitative and qualitative analysis of EEG and clinical findings. Acta Neurol Scand 1991; 83(6): 411 - 17.
107 | Kuyk J, Spinhoven P, van Dyck R. Hypnotic recall: A positive criterion in the differential diagnosis between epileptic and pseudoepileptic seizures. Epilepsia 1999; 40(4): 485 - 91.
108 | Kuzniecky R, Andermann F, Guerrini R. Congenital bilateral perisylvian syndrome: Study of 31 patients. The CBPS Multicenter Collaborative Study. Lancet 1993; 341(8845): 608 - 12.
109 | Kuzniecky R, Faught E, Morawetz R. Electroencephalographic correlations of extracranial and epidural electrodes in temporal lobe epilepsy. Epilepsia 1991; 32(3): 335 - 40.
110 | Lancman ME, Asconape JJ, Penry JK. Clinical and EEG asymmetries in juvenile myoclonic epilepsy. Epilepsia 1994; 35(2): 302 - 06.
111 | Lancman ME, Brotherton TA, Asconape JJ, et al. Psychogenic seizures in adults: A longitudinal analysis. Seizure 1993; 2(4): 281 - 86.
112 | Lanska MJ, Lanska DJ, Baumann RJ, et al. Interobserver variability in the classification of neonatal seizures based on medical record data. Pediatr Neurol 1996; 15(2): 120 - 23.
113 | Lawson JA, Cook MJ, Bleasel AF, et al. Quantitative MRI in outpatient childhood epilepsy. Epilepsia 1997; 38(12): 1289 - 93.
114 | Lawson JA, Nguyen W, Bleasel AF, et al. ILAE-defined epilepsy syndromes in children: Correlation with quantitative MRI. Epilepsia 1998; 39(12): 1345 - 49.
115 | Leis AA, Ross MA, Summers AK. Psychogenic seizures: Ictal characteristics and diagnostic pitfalls. Neurology 1992; 42(1): 95 - 9.
116 | Lelliott PT, Fenwick P. Cerebral pathology in pseudoseizures. Acta Neurol Scand 1991; 83(2): 129 - 32.
117 | Leutmezer F, Serles W, Lehrner J, et al. Postictal nose wiping: A lateralizing sign in temporal lobe complex partial seizures. Neurology 1998; 51(4): 1175 - 77.
118 | Levin R, Leaton EM, Lee SI. The value of nasopharyngeal recording in psychiatric patients. Biol Psychiatry 1986; 21(13): 1236 - 38.
119 | MacIntosh DS, Camfield PR, Camfield CS. Children with familial cryptogenic epilepsy have a favorable seizure prognosis. J Child Neurol 1998; 13(8): 372 - 76.
120 | Manaka S. Cooperative prospective study on posttraumatic epilepsy: Risk factors and the effect of prophylactic anticonvulsant. Jpn J Psychiatry Neurol 1992; 46(2): 311 - 15.
121 | Manford M, Fish DR, Shorvon SD. An analysis of clinical seizure patterns and their localizing value in frontal and temporal lobe epilepsies. Brain 1996; 119(Pt 1): 17 - 40.
122 | Manzano GM, Ragazzo PC, Tavares SM, et al. Anterior zygomatic electrodes: A special electrode for the study of temporal lobe epilepsy. Appl Neurophysiol 1986; 49(4): 213 - 17.
123 | Martin RC, Gilliam FG, Kilgore M, et al. Improved health care resource utilization following video-EEG-confirmed diagnosis of nonepileptic psychogenic seizures. Seizure 1998; 7(5): 385 - 90.
124 | Masuoka LK, Anderson AW, Gore JC, et al. Functional magnetic resonance imaging identifies abnormal visual cortical function in patients with occipital lobe epilepsy. Epilepsia 1999; 40(9): 1248 - 53.
125 | McIntosh S, Da Costa D, Kenny RA. Outcome of an integrated approach to the investigation of dizziness, falls and syncope in elderly patients referred to a 'syncope' clinic. Age Ageing 1993; 22(1): 53 - 8.
126 | McLean MJ, Morrell MJ, Willmore LJ, et al. Safety and tolerability of gabapentin as adjunctive therapy in a large, multicenter study. Epilepsia 1999; 40(7): 965 - 72.
127 | Meierkord H, Will B, Fish D, et al. The clinical features and prognosis of pseudoseizures diagnosed using video-EEG telemetry. Neurology 1991; 41(10): 1643 - 46.
128 | Mervaala E, Partanen J, Nousianinen U, et al. Electrophysiologic effects of gamma-vinyl GABA and carbamazepine. Epilepsia 1989; 30(2): 189 - 93.
129 | Miller JW, Yanagihara T, Petersen RC, et al. Transient global amnesia and epilepsy. Electroencephalographic distinction. Arch Neurol 1987; 44(6): 629 - 33.
130 | Mishra V, Gahlaut DS, Kumar S, et al. Value of serum prolactin in differentiating epilepsy from pseudoseizure. JAPI 1990; 38(11): 846 - 47.
131 | Mitsuyoshi I, Tamaki K, Okuno T, et al. Regional cerebral blood flow in diagnosis of childhood onset partial epilepsy. Brain Dev 1993; 15(2): 97 - 102.
132 | Murthy JM, Mohan Rao CH, Meena AK. Clinical observations of juvenile myoclonic epilepsy in 131 patients: A study in South India. Seizure 1998; 7(-): 43 - 7.
133 | Murthy JM, Reddy VS. Clinical characteristics, seizure spread patterns and prognosis of seizures associated with a single small cerebral calcific CT lesion. Seizure 1998; 7(2): 153 - 57.
134 | Nagarajan L, Bye AM. Staring episodes in children analyzed by telemetry. J Child Neurol 1992; 7(1): 39 - 43.
135 | Neufeld MY, Cohn DF, Korczyn AD. Sphenoidal EEG recording in complex partial seizures. Clin Electroencephalogr 1986; 17(3): 139 - 41.
136 | Ogunniyi A, Adeyinka A, Fagbemi SO, et al. Computerized tomographic findings in adolescent and adult Nigerian epileptics. West Afr J Med 1994; 13(2): 128 - 31.
137 | Okuno T, Ito M, Nakano S, et al. Carbamazepine therapy and long-term prognosis in epilepsy of childhood. Epilepsia 1989; 30(1): 57 - 61.
138 | Oldani A, Zucconi M, Asselta R, et al. Autosomal dominant nocturnal frontal lobe epilepsy. A video-polysomnographic and genetic appraisal of 40 patients and delineation of the epileptic syndrome. Brain 1998; 121(Pt. 2): 205 - 223.
139 | Ortibus EL, Sum JM, Hahn JS. Predictive value of EEG for outcome and epilepsy following neonatal seizures. Electroencephalogr Clin Neurophysiol 1996; 98(3): 175 - 85.
140 | Pacifici R, Zuccaro P, Iannetti P, et al. Immunologic aspects of vigabatrin treatment in epileptic children. Epilepsia 1995; 36(4): 423 - 26.
141 | Padma MV, Behari M, Misra NK, et al. Albendazole in single CT ring lesions in epilepsy. Neurology 1994; 44(7): 1344 - 46.
142 | Palmini A, Andermann F, Olivier A, et al. Neuronal migration disorders: A contribution of modern neuroimaging to the etiologic diagnosis of epilepsy. Can J Neurol Sci 1991; 18 Suppl(4): 580 - 87.
143 | Panayiotopoulos CP. Elementary visual hallucinations in migraine and epilepsy . J Neurol Neurosurg Psychiatry 1994; 57(11): 1371 - 74.
144 | Panayiotopoulos CP, Koutroumanidis M, Giannakodimos S, et al. Idiopathic generalised epilepsy in adults manifested by phantom absences, generalised tonic-clonic seizures, and frequent absence status. J Neurol Neurosurg Psychiatry 1997; 63(5): 622 - 27.
145 | Panayiotopoulos CP, Obeid T, Waheed G. Absences in juvenile myoclonic epilepsy: A clinical and video-electroencephalographic study. Ann Neurol 1989; 25(4): 391 - 97.
146 | Panet-Raymond D, Gotman J. Asymmetry in delta activity in patients with focal epilepsy. Electroencephalogr Clin Neurophysiol 1990; 75(6): 474 - 81.
147 | Parra J, Iriarte J, Kanner AM. are we overusing the diagnosis of psychogenic non-epileptic events? Seizure 1999; 8(4): 223 - 7.
148 | Peiris JB, Karunanayake EH, Joice PD, et al. Relationship between dose and serum concentrations of carbamazepine, phenytoin, phenobarbital, and primidone in a Sri Lankan population compared with a European population. Epilepsia 1988; 29(5): 564 - 70.
149 | Peled R, Lavie P. Paroxysmal awakenings from sleep associated with excessive daytime somnolence: A form of nocturnal epilepsy. Neurology 1986; 36(1): 95 - 98.
150 | Pietz J, Benninger C, Schafer H, et al. Treatment of infantile spasms with high-dosage vitamin B6. Epilepsia 1993; 34(4): 757 - 63.
151 | Psatta DM, Matei M, Jipescu I. Contribution of EEG mapping to diagnosis setting in a supratentorial damage. Rom J Neurol Psychiatry 1990; 28(2): 87 - 96.
152 | Psatta DM, Tudorache B, Matei M, et al. Cerebral dysfunction revealed by EEG mapping in the schizoform epileptic psychosis. Rom J Neurol Psychiatry 1991; 29(1 - 2): 81 - 98.
153 | Puce A, Andrewes DG, Berkovic SF, et al. Visual recognition memory. Neurophysiological evidence for the role of temporal white matter in man. Brain 1991; 114(4): 1647 - 66.
154 | Puri V, Gupta RK. Magnetic resonance imaging evaluation of focal computed tomography abnormality in epilepsy. Epilepsia 1991; 32(4): 460 - 66.
155 | Rabinowicz AL, Correale J, Boutros RB, et al. Neuron-specific enolase is increased after single seizures during inpatient video/EEG monitoring. Epilepsia 1996; 37(2): 122 - 25.
156 | Ramchandani D, Schindler B. Evaluation of pseudoseizures. A psychiatric perspective. Psychosomatics 1993; 34(1): 70 - 79.
157 | Raroque HGJ, Gonzales PC, Jhaveri HS, et al. Defining the role of structural lesions and metabolic abnormalities in periodic lateralized epileptiform discharges. Epilepsia 1993; 34(2): 279 - 83.
158 | Raroque HGJ, Wagner W, Gonzales PC, et al. Reassessment of the clinical significance of periodic lateralized epileptiform discharges in pediatric patients. Epilepsia 1993; 34(2): 275 - 78.
159 | Resta M, Palma M, Dicuonzo F, et al. Imaging studies in partial epilepsy in children and adolescents. Epilepsia 1994; 35(6): 1187 - 93.
160 | Reutens DC, Berkovic SF, Macdonell RA, et al. Magnetic stimulation of the brain in generalized epilepsy: Reversal of cortical hyperexcitability by anticonvulsants. Ann Neurol 1993; 34(3): 351 - 55.
161 | Riaz H, Comish S, Lawton L, et al. Non-epileptic attack disorder and clinical outcome: A pilot study. Seizure 1998; 7(5): 365 - 68.
162 | Rosenow F, Wyllie E, Kotagal P, et al. Staring spells in children: Descriptive features distinguishing epileptic and nonepileptic events. J Pediatr 1998; 133(5): 660 - 63.
163 | Ross CA, Heber S, Anderson G, et al. Differentiating multiple personality disorder and complex partial seizures. Gen Hosp Psychiatry 1989; 11(1): 54 - 8.
164 | Ryback RS, Gardner EA. Limbic system dysrhythmia: A diagnostic electroencephalogram procedure utilizing procaine activation. J Neuropsychiatry Clin Neurosci 1991; 3(3): 321 - 29.
165 | Ryglewicz D, Baranska-Gieruszczak M, Niedzielska K, et al. EEG and CT findings in poststroke epilepsy. Acta Neurol Scand 1990; 81(6): 488 - 90.
166 | Saccomani L, Cirrincione M, Savoini M. Pseudo-epileptic seizures in children and adolescents. Dev Med Child Neurol 1993; 35(4): 359 - 61.
167 | Samuel M, Duncan JS. Use of the hand held video camcorder in the evaluation of seizures. J Neurol Neurosurg Psychiatry 1994; 57(11): 1417 - 18.
168 | Sanchez-Alcaraz A, Quintana MB, Lopez E, et al. Valproic acid clearance in children with epilepsy. J Clin Pharm Ther 1998; 23(1): 31 - 34.
169 | Sansom D, Krishnan VH, Corbett J, et al. Emotional and behavioural aspects of Rett syndrome. Dev Med Child Neurol 1993; 35(4): 340 - 45.
170 | Saygi S, Spencer SS, Scheyer R, et al. Differentiation of temporal lobe ictal behavior associated with hippocampal sclerosis and tumors of temporal lobe. Epilepsia 1994; 35(4): 737 - 42.
171 | Schachter SC, Ito M, Wannamaker BB, et al. Incidence of spikes and paroxysmal rhythmic events in overnight ambulatory computer-assisted eegs of normal subjects: A multicenter study. J Clin Neurophysiol 1998; 15(3): 251 - 5.
172 | Scheepers B, Budd S, Curry S, et al. Non-epileptic attack disorder: A clinical audit. Seizure 1994; 3(2): 129 - 34.
173 | Scheepers B, Clough P, Pickles C. The misdiagnosis of epilepsy: Findings of a population study. Seizure 1998; 7(5): 403 - 6.
174 | Scher MS, Hamid MY, Steppe DA, et al. Ictal and interictal electrographic seizure durations in preterm and term neonates. Epilepsia 1993; 34(2): 284 - 88.
175 | Schofield A, Duane MM. Neurologic referrals to a psychiatric consultation-liaison service. A study of 199 patients. Gen Hosp Psychiatry 1987; 9(4): 280 - 86.
176 | Selwa LM, Buchtel HA, Henry TR. Electrocerebral recovery during the intracarotid amobarbital procedure: Influence of interval between injections. Epilepsia 1997; 38(12): 1294 - 99.
177 | Singh R, Scheffer IE, Crossland K, et al. Generalized epilepsy with febrile seizures plus: A common childhood-onset genetic epilepsy syndrome. Ann Neurol 1999; 45(1): 75 - 81.
178 | Siregar P, Toulouse P. Model-based diagnosis of brain disorders: A prototype framework. Artif Intell Med 1995; 7(4): 315 - 42.
179 | Slater JD, Brown MC, Jacobs W, et al. Induction of pseudoseizures with intravenous saline placebo. Epilepsia 1995; 36(6): 580 - 85.
180 | Smith D, Defalla BA, Chadwick DW. The misdiagnosis of epilepsy and the management of refractory epilepsy in a specialist clinic. QJM 1999; 92(1): 15 - 23.
181 | Spencer SS, Williamson PD, Bridgers SL, et al. Reliability and accuracy of localization by scalp ictal EEG. Neurology 1985; 35(11): 1567 - 75.
182 | Sunaga Y, Hikima A, Otsuka T, et al. P300 event-related potentials in epileptic children. Clin Electroencephalogr 1994; 25(1): 13 - 17.
183 | Sung CY, Chu NS. Epileptic seizures in elderly people: Aetiology and seizure type. Age Ageing 1990; 19(1): 25 - 30.
184 | Swartz BE, Halgren E, Delgado-Escueta AV, et al. Multidisciplinary analysis of patients with extratemporal complex partial seizures. I. Intertest agreement. Epilepsy Res 1990; 5(1): 61 - 73.
185 | Swartz BE, Halgren E, Delgado-Escueta AV, et al. Neuroimaging in patients with seizures of probable frontal lobe origin. Epilepsia 1989; 30(5): 547 - 558.
186 | Tardy B, Lafond P, Convers P, et al. Adult first generalized seizure: Etiology, biological tests, EEG, CT scan, in an ED. Am J Emerg Med 1995; 13(1): 1 - 5.
187 | Tartara A, Manni R. Diagnostic value of spontaneous afternoon sleep in epilepsy: Polysomnographic study of 96 epileptic patients. Eur Neurol 1986; 25(1): 26 - 31.
188 | Tatum WO, Alavi A, Stecker MM. Technetium-99m-HMPAO SPECT in partial status epilepticus. J Nucl Med 1994; 35(7): 1087 - 94.
189 | ter Maaten JC, Strack SR, Heimans JJ, et al. Ten patients with refractory status epilepticus in an intensive care department. Neth J Med 1998; 53(6): 260 - 65.
190 | Terzano MG, Parrino L, Spaggiari MC, et al. Discriminatory effect of cyclic alternating pattern in focal lesional and benign rolandic interictal spikes during sleep. Epilepsia 1991; 32(5): 616 - 28.
191 | Thilothammal N, Kannan, Krishnamurthy PV, et al. Role of phenobarbitone in preventing recurrence of febrile convulsions. Indian Pediatr 1993; 30(5): 637 - 42.
192 | Thomaides TN, Kerezoudi EP, Chaudhuri KR, et al. Study of EEGs following 24-hour sleep deprivation in patients with posttraumatic epilepsy. Eur Neurol 1992; 32(2): 79 - 82.
193 | Thoresen M, Henriksen O, Wannag E, et al. Does a sedative dose of chloral hydrate modify the EEG of children with epilepsy? Electroencephalogr Clin Neurophysiol 1997; 102(2): 152 - 57.
194 | Touchon J, Valmier J, Baldy-Moulinier M, et al. Regional cerebral blood flow during interictal state: Differences between temporal lobe epilepsy and primary generalized epilepsy. Eur Neurol 1986; 25(1): 43 - 52.
195 | Varma AR, Moriarty J, Costa DC, et al. HMPAO SPECT in non-epileptic seizures: Preliminary results. Acta Neurol Scand 1996; 94(2): 88 - 92.
196 | Vining EPG, Mellitis ED, Dorsen MM, et al. Psychologic and behavioral effects of antiepileptic drugs in children: A double-blind comparison between phenobarbital and valproic acid. Pediatrics 1987; 80(2): 165 - 74.
197 | Walczak TS, Bogolioubov A. Weeping during psychogenic nonepileptic seizures. Epilepsia 1996; 37(2): 208 - 10.
198 | Walczak TS, Williams DT, Berten W. Utility and reliability of placebo infusion in the evaluation of patients with seizures. Neurology 1994; 44(3 Pt 1): 394 - 99.
199 | Watanabe K, Takahashi I, Negoro T, et al. Benign epilepsy of children with complex partial seizures following febrile convulsions. Seizure 1993; 2(1): 57 - 61.
200 | Weglage J, Demsky A, Pietsch M, et al. Neuropsychological, intellectual, and behavioral findings in patients with centrotemporal spikes with and without seizures. Dev Med Child Neurol 1997; 39(10): 646 - 51.
201 | Westbrook LE, Devinsky O, Geocadin R. Nonepileptic seizures after head injury. Epilepsia 1998; 39(9): 978 - 82.
202 | Williams BA, Abbott KJ, Manson JI. Cerebral tumors in children presenting with epilepsy. J Child Neurol 1992; 7(3): 291 - 94.
203 | Williamson A, Spencer SS, Spencer DD. Depth electrode studies and intracellular dentate granule cell recordings in temporal lobe epilepsy. Ann Neurol 1995; 38(5): 778 - 87.
204 | Wolf P, Okujava N. Possibilities of non-pharmacological conservative treatment of epilepsy. Seizure 1999; 8(1): 45 - 52.
205 | Wolf SM, Forsythe A. Epilepsy and mental retardation following febrile seizures in childhood. Acta Paediatr Scand 1989; 78(2): 291 - 95.
206 | Wyllie E, Lueders H, Pippenger C, et al. Postictal serum creatine kinase in the diagnosis of seizure disorders. Arch Neurol 1985; 42(2): 123 - 26.
207 | Zaidi A, Crampton S, Clough P, et al. Head-up tilting is a useful provocative test for psychogenic non-epileptic seizures. Seizure 1999; 8(6): 353 - 5.
208 | Zelnik N, Kahana L, Rafael A, et al. Prolactin and cortisol levels in various paroxysmal disorders in childhood. Pediatrics 1991; 88(3): 486 - 89.

Rejection | Outcomes not extractable
1 | Aguglia U, Gambardella A, Le Piane E, et al. Chlorpromazine versus sleep deprivation in activation of EEG in adult-onset partial epilepsy. J Neurol 1994; 241(10): 605 - 10.
2 | Appleton R, Besag F, Kennedy C, et al. An audit of children referred with suspected epilepsy. Seizure 1998; 7(6): 489 - 95.
3 | Baldy-Moulinier M, Covanis A, D'Urso S, et al. Therapeutic strategies against epilepsy in mediterranean countries: A report from an international collaborative survey. Seizure 1998; 7(6): 513 - 20.
4 | Besser R, Hornung K, Theisohn M, et al. EEG changes in patients during the introduction of carbamazepine. Electroencephalogr Clin Neurophysiol 1992; 83(1): 19 - 23.
5 | Brown S, Betts T, Crawford P, et al. Epilepsy needs revisited: A revised epilepsy needs document for the UK. Seizure 1998; 7(6): 435 - 46.
6 | Drury I, Selwa LM, Schuh LA, et al. Value of inpatient diagnostic CCTV-EEG monitoring in the elderly. Epilepsia 1999; 40(8): 1100 - 02.
7 | Eadie MJ. Plasma antiepileptic drug monitoring in a neurological practice: A 25-year experience. Ther Drug Monit 1994; 16(5): 458 - 68.
8 | Eriksson KJ, Koivikko MJ. Prevalence, classification, and severity of epilepsy and epileptic syndromes in patients. Epilepsia 1997; 38(12): 1275 - 1282.
9 | Falope ZF, Ogunniyi A, Osuntokun BO. Factors associated with epileptiform EEG patterns in Nigerian epileptics. East Afr Med J 1993; 70(5): 294 - 96.
10 | Ferrarese C, Cogliati T, Tortorella R, et al. Diazepam binding inhibitor (DBI) in the plasma of pediatric and adult epileptic patients. Epilepsy Res 1998; 29(2): 129 - 34.
11 | Hamer HM, Wyllie E, Luders HO, et al. Symptomatology of epileptic seizures in the first three years of life. Epilepsia 1999; 40(7): 837 - 44.
12 | Kallen B. A register study of maternal epilepsy and delivery outcome with special reference to drug use. Acta Neurol Scand 1986; 73(3): 253 - 59.
13 | Kaplan PW. Nonconvulsive status epilepticus in the emergency room. Epilepsia 1996; 37(7): 643 - 50.
14 | Krumholz A, Grufferman S, Orr ST, et al. Seizures and seizure care in an emergency department. Epilepsia 1989; 30(2): 175 - 181.
15 | Lancman ME, O'Donovan C, Dinner D, et al. Usefulness of prolonged video-EEG monitoring in the elderly. J Neurol Sci 1996; 142(1 - 2): 54 - 8.
16 | Lee AG, Delgado-Escueta AV, Maldonado HM, et al. Closed-circuit television videotaping and electroencephalography biotelemetry (video/EEG) in primary generalized epilepsies. Adv Neurol 1987; 46(-): 27 - 68.
17 | Matuja WB, Ndosi N. Electroencephalographic findings in Tanzanian epileptic patients. Afr J Med Sci 1993; 22(3): 17 - 20.
18 | Yager JY, Cheang M, Seshia SS. Status epilepticus in children. Can J Neurol Sci 1988; 15(4): 402 - 5.

Rejection | Pharmacokinetic / Pharmacodynamic Study
1 | Hussein Z, Posner J. Population pharmacokinetics of lamotrigine monotherapy in patients with epilepsy: Retrospective analysis of routine monitoring data. Br J Clin Pharmacol 1997; 43(5): 457 - 65.
2 | Sachdeo R, Narang-Sachdeo SK, Shumaker RC, et al. Tolerability and pharmacokinetics of monotherapy felbamate doses of 1,200 - 6,000 mg/day in subjects with epilepsy. Epilepsia 1997; 38(8): 887 - 92.

Rejection | Results for population of interest are not separable from other populations
1 | Bridgers SL, Ebersole JS. The clinical utility of ambulatory cassette EEG. Neurology 1985; 35(2): 166 - 73.
2 | Bridgers SL, Ebersole JS. Incidence of seizures with phenytoin toxicity. Neurology 1985; 35(-): 1767 - 68.
3 | Futagi Y, Otani K, Imai K. Reduction in internal carotid arterial blood flow velocity in children during antiepileptic drug therapy with clinical dosages. Epilepsia 1994; 35(4): 827 - 31.
4 | Gibbs J, Appleton RE, Carty H, et al. Focal electroencephalographic abnormalities and computerised tomography findings in children with seizures. J Neurol Neurosurg Psychiatry 1993; 56(4): 369 - 71.
5 | Hopkins A, Garman A, Clarke C. The first seizure in adult life: Value of clinical features, electroencephalography, and computerized tomographic scanning in prediction of seizure recurrence. Lancet 1988; 1(-): 721 - 26.
6 | Laxer KD, Mullooly JP, Howell B. Prolactin changes after seizures classified by EEG monitoring. Neurology 1985; 35(1): 31 - 5.
7 | Marciani MG, Gigli GL, Stefanini F, et al. Effect of carbamazepine on EEG background activity and on interictal epileptiform abnormalities in focal epilepsy. Int J Neurosci 1993; 70(1 - 2): 107 - 116.
8 | Marciani MG, Stanzione P, Maschio M, et al. EEG changes induced by vigabatrin monotherapy in focal epilepsy. Acta Neurol Scand 1997; 95(2): 115 - 20.
9 | Reunanen M, Dam M, Yuen AWC. A randomised open multicentre comparative trial of lamotrigine and carbamazepine as monotherapy in patients with newly diagnosed or recurrent epilepsy. Epilepsy Res 1996; 23(-): 149 - 55.

Rejection | Reviews, meta-analyses, letters, case reports, editorials, and commentaries
1 | Alldredge BK. Seizure risk associated with psychotropic drugs: Clinical and pharmacokinetic considerations. Neurology 1999; 53 Suppl 2(5): 68 - 75.
2 | American Academy of Pediatrics. Provisional Committee on Quality Improvement, Subcommittee on Febrile Seizures. Practice parameter: The neurodiagnostic evaluation of the child with a first simple febrile seizure. Pediatrics 1996; 97(5): 769 - 72.
3 | Applegate MS, Lo W. Febrile seizures: Current concepts concerning prognosis and clinical management. J Fam Pract 1989; 29(4): 422 - 28.
4 | Appleton RE, Neville BG. Teenagers with epilepsy. Arch Dis Child 1999; 81(1): 76 - 9.
5 | Baker GA, Nashef L, van Hout BA. Current issues in the management of epilepsy: The impact of frequent seizures on the cost of illness, quality of life, and mortality. Epilepsia 1997; 38(Suppl 1): 1 - 8.
6 | Beran RG. Medical management of epilepsy. Aust Fam Physician 1989; 18(2): 135 - 6.
7 | Beran RG, Tilley M. Clinical trials of antiepileptic drugs performed in the private practice setting. Epilepsia 1994; 35(1): 101 - 106.
8 | Berg AT, Shinnar S. The risk of seizure recurrence following a first unprovoked seizure: A quantitative review. Neurology 1991; 41(-): 965 - 72.
9 | Callaghan N, Goggin T. Adjunctive therapy in resistant epilepsy. Epilepsia 1988; 29 Suppl 1(-): 29 - 35.
10 | Cochrane HC, Marson AG, Baker GA, et al. Neuropsychological outcomes in randomized controlled trials of antiepileptic drugs: A systematic review of methodology and reporting standards. Epilepsia 1998; 39(10): 1088 - 1097.
11 | Dahl M, Dam M. Sleep and epilepsy. Ann Clin Res 1985; 17(5): 235 - 42.
12 | Dodson WE. Aspects of antiepileptic treatment in children. Epilepsia 1988; 29(-): 10 - 14.
13 | Dodson WE. Carbamazepine efficacy and utilization in children. Epilepsia 1987; 28(-): 17 - 24.
14 | Dodson WE. Special pharmacokinetic considerations in children. Epilepsia 1987; 28(-): 56 - 70.
15 | Dulac O, Plouin P, Shewmon A. Myoclonus and epilepsy in childhood: 1996 Royaumont meeting. Epilepsy Res 1998; 30(2): 91 - 106.
16 | Duncan JS. Antiepileptic drugs and the electroencephalogram. Epilepsia 1987; 28(3): 259 - 66.
17 | Edmondstone WM. Clinical management. Fits, faints and funny turns. J R Nav Med Serv 1997; 83(2): 76 - 78.
18 | Evans OB. Symptomatic seizures. Pediatr Ann 1999; 28(4): 231 - 37.
19 | Francis P, Baker GA. Non-epileptic attack disorder (NEAD): A comprehensive review. Seizure 1999; 8(1): 53 - 61.
20 | Gilbert K. An algorithm for diagnosis and treatment of status epilepticus in adults. J Neurosci Nurs 1999; 31(1): 27 - 36.
21 | Guberman A. Hormonal contraception and epilepsy. Neurology 1999; 53 Suppl 1(4): 38 - 40.
22 | Haafiz A, Kissoon N. Status epilepticus: Current concepts. Ped Emerg Care 1999; 15(2): 119 - 29.
23 | Heaney DC, Sander JS. Cost-effectiveness model of adjunctive lamotrigine for the treatment of epilepsy. Neurology 1999; 53(3): 657 - 58.
24 | Heaney DC, Shorvon SD, Sander JW. An economic appraisal of carbamazepine, lamotrigine, phenytoin and valproate as initial treatment in adults with newly diagnosed epilepsy. Epilepsia 1998; 39 Suppl(-): 19 - 25.
25 | Hingley AT. Epilepsy: Taming the seizures, dispelling the myths. FDA Consum 1999; 33(1): 28 - 32.
26 | Jordan KG. Nonconvulsive status epilepticus in acute brain injury. J Clin Neurophysiol 1999; 16(4): 332 - 40.
27 | Kaplan PW. Assessing the outcomes in patients with nonconvulsive status epilepticus: Nonconvulsive status epilepticus is underdiagnosed, potentially overtreated, and confounded by comorbidity. J Clin Neurophysiol 1999; 16(4): 341 - 52.
28 | King-Stephens D. The treatment of epilepsy in the elderly. CNS Drugs 1999; 12(1): 21 - 33.
29 | Long L, McAuley JW. Epilepsy: A review of seizure types, etiologies, diagnosis, treatment, and nursing implications. Crit Care Nurse 1996; 16(4): 83 - 92.
30 | Mattson RH. Medical management of epilepsy in adults. Neurology 1998; 51 Suppl 4(5): 15 - 20.
31 | McNamara JO. Emerging insights into the genesis of epilepsy. Nature 1999; 399 Suppl(6738): 15 - 22.
32 | Mellor D. When to start anticonvulsant treatment in childhood epilepsy: The case for avoiding or delaying treatment. Br Med J 1988; 297(6662): 1529 - 30.
33 | Morey SS. Neurologic group develops recommendations for management of epilepsy. Am Fam Phys 1999; 59(9): 2648 - 53.
34 | Ozkara C, Dreifuss FE. Differential diagnosis in pseudoepileptic seizures. Epilepsia 1993; 34(2): 294 - 98.
35 | Panayiotopoulos CP. Early-onset benign childhood occipital seizure susceptibility syndrome: A syndrome to recognize. Epilepsia 1999; 40(5): 621 - 30.
36 | Panayiotopoulos CP. Significance of the EEG after the first afebrile seizure. Arch Dis Child 1998; 78(6): 575 - 76.
37 | Panayiotopoulos CP, Agathonikou A, Sharoqi IA, et al. Vigabatrin aggravates absences and absence status. Neurology 1997; 49(5): 1467.
38 | Pellock JM. Treatment of seizures and epilepsy in children and adolescents. Neurology 1998; 51 Suppl 4(5): 8 - 14.
39 | Porter RJ. Recognizing and classifying epileptic seizures and epileptic syndromes. Neurol Clin 1986; 4(3): 495 - 508.
40 | Rapin I. Practitioner review: Developmental language disorders: A clinical update. J Child Psychol Psychiatry 1996; 37(6): 643 - 55.
41 | Rose VL. New guidelines offer recommendations for women with epilepsy. Am Fam Physician 1999; 59(6): 1681 - 82.
42 | Rudkin TM, Arnold DL. Proton magnetic resonance spectroscopy for the diagnosis and management of cerebral disorders. Archives of Neurology 1999; 56(8): 919 - 26.
43 | Sato S, Long RL, Porter RJ. Monitoring at the National Institute of Neurological and Communicative Disorders and Stroke. Electroencephalogr Clin Neurophysiol Suppl 1985; 37(-): 415 - 22.
44 | Scamvougeras A. Psychiatric comorbidity in epilepsy: basic mechanisms, diagnosis and treatment. Can J Neurol Sci 1999; 44(2): 185 - 6.
45 | Shafer PO. Epilepsy and seizures: Advances in seizure assessment, treatment, and self-management. Nurs Clin North Am 1999; 34(3): 743 - 59.
46 | Shinnar S, Ballaban-Gil K. An approach to the child with a first unprovoked seizure. Pediatr Ann 1991; 20(1): 29 - 33.
47 | Sperling MR, Engel JJ. Sphenoidal electrodes. J Clin Neurophysiol 1986; 3(1): 67 - 73.
48 | Vedanarayanan VV. Diagnosis of epilepsy in children. Pediatr Ann 1999; 28(4): 218 - 24.
49 | Williamson PD, Spencer SS. Clinical and EEG features of complex partial seizures of extratemporal origin. Epilepsia 1986; 27 Suppl 2(-): 46 - 63.
50 | Willmore LJ. Epilepsy emergencies - The first seizure and status epilepticus. Neurology 1998; 51 Suppl 4(5): 34 - 38.
51 | Wszolek ZK, Groover RV, Klass DW. Seizures presenting as episodic hypersomnolence. Epilepsia 1995; 36(1): 108 - 110.
52 | Zapata-Ferrer A, Rivas ML, Gaona GA, et all. Detecting the onset of epileptic seizures. IEEE Eng Med Biol Mag 1999; 18(3): 78 - 83.

## Appendix 9: Studies Pending

1. Battaglia D, Rando T, Deodato F. Epileptic disorders with onset in the first year of life: Neurological and cognitive outcome. Eur J Pediatr Neurol 1999; 3(3): 95 - 103.; 2. Hajek M, Dezortova M, Komarek V. H MR spectroscopy in patients with mesial temporal epilepsy. MAGMA 1998; 7(2): 95 - 114.; 3. Malmgren K, Blennow G, Hedstrom A. Differential diagnosis in epilepsy. Lakartidningen 1997; 94(21): 1985 - 90.; 4. Martinez Bermejo A, Pascual-Castroviejo, IP. The diagnosis and treatment of partial epilepsy in adolescents. Neurologia 1996; 11 Suppl(4): 58 - 71.; 5. Martinez M. Clinical and diagnostic characteristics in status epilepticus. Neurologia 1997; 12(6): 25 - 30.; 6. Nowack WJ. Epilepsy: A costly misdiagnosis. Clin Electroencephal 1997; 28(4): 225 - 228.; 7. Thompson JE, Castillo M, Kwock L. MR spectroscopy in the evaluation of epilepsy. MRI Clin North Am 1998; 6(1): 21 - 29.

## Appendix 10. Technical Expert Panel (TEP) Members

Panel Members | Specialty/Category | Affiliation
Gregory L. Barkley, M.D. | Epilepsy Specialist | Medical Director, Henry Ford Comprehensive Epilepsy Program, Detroit, MI
Joyce Bender | Consumer Advocate | Bender Consulting Services, Inc. Pittsburgh, Pennsylvania
Patricia Dean, MSN, MS | Epilepsy Specialist | Miami Children's Hospital Miami, Florida
Margaret Gunter, PhD | Health Services | Lovelace Clinic Foundation Alburquerque, New Mexico
Suzanne Mercure | Health Services | Institute for Health Policy Solutions Falls Church, Virginia
David Stumpf, M.D., PhD | Neurologist | Northwestern University Medical School, Chicago, Illinois
Louis Trost, M.D. | Primary Care | Lovelace Family Practice - Westside Alburquerque, New Mexico
Linda Warner | Consumer Advocate | Forest Lake, Minnesota

## Appendix 11. Peer Review Panel

Peer Review Panel | Specialty/Category | Affiliation
Javier Aceves, M.D. | Primary Care | Pediatrics - Lovelace Health Systems Rio Rancho, New Mexico
Claire Chee, RN | Pediatric Epilepsy Specialist | Current President of ACNN Children's Hospital of Philadelphia
Stephen Collins, M.D. | Industry Representative | Abbott
Patricia Crumrine, M.D. | Neurologist | Children's Hospital, Pittsburgh, PA. (Representing American Academy of Pediatrics)
Joseph D'Souza, PhD | Industry Representative | Novartis
John Gates, M.D. | Epilepsy specialist | Minnesota Epilepsy Group, St. Paul, Minnesota
Elizabeth Garofalo, M.D. | Neurologist, Industry Representative | Parke-Davis
Frank Gilliam, M.D., MPH | Epilepsy Specialist | Washington University School of Medicine, Dept. of Neurology - St. Louis, MO
Robert Gumnit, M.D. | Epilepsy Specialist | President, Nat'l Association of Epilepsy Centers MINCEP Epilepsy Care, Minneapolis, MN
Cynthia Joyce | Consumer Advocate | Director, Education and Research Foundation of the American Academy of Neurology
Allan Krumholz, M.D. | Epilepsy Specialist | Univ. of Maryland, Dept. of Neurology
Lisa Lindahl | Consumer Advocate | Spear-headed the Women's Initiative" for the Epilepsy Foundation.
Janet Mims, RN | Consumer Advocate | Past President of Assoc. of Child Neurology Nurses(ACNN)
Martha J. Morrell, M.D. | Epilepsy Specialist | Professor, New York Presbyterian Hosp. Chair, Epilepsy Foundation Board of Directors
Jay Rosenberg, M.D. | Neurologist | San Diego, CA
Steven Schachter, M.D. | Epilepsy Specialist | Beth Israel Deaconess Comprehensive Epilepsy Center, Chair, Epilepsy Foundation Professional Advisory Board.
Stephen Schwabe, M.D. | Industry Representative | Johnson & Johnson
Patricia Shafer, RN | Epilepsy Specialist | BI Deaconess Medical Center, Boston, MA Chair Elect, Epilepsy Foundation Professional Advisory Board
Kari Swarztrauber, M.D. | Neurologist | Post Doctoral Fellow - UCLA Dept of Neurology

## Appendix 12: Peer Reviewer Form

A Systematic Review of the Literature Regarding the Management of Patients with a First Diagnosis of Epilepsy

Please indicate your level of agreement with each of the following statements, by placing an "X" in the appropriate column.
Statements | Very much agree | Moderately agree | Not very much in agreement | Do not agree at all
1. This topic is relevant to healthcare decision-making (clinical practice and policy making) in 2000.
2. The criteria used to select articles for inclusion were appropriate.
3. Based on selection criteria used, it is not likely that relevant studies were missed.
4. The validity of the studies was appraised appropriately.
5. The methods are presented in such a way as to be reproducible.
6. The statistical analytic methods are appropriate to the material and the objectives.
7. The results are stated clearly.
8. Given the nature of the topic and the data, all clinically important outcomes were considered.
9. I agree with the conclusions presented in the report.

On the following page, please provide: | a. A brief explanation of both positive and negative answers;; b. Suggestions for improvement of the content or format of this review;; c. Suggestions for additional analyses of this dataset worth including in this report, or in future reports.

**We would prefer that you complete and return this form electronically. However, you may also fax the form back to us, or fax back an annotated version of the draft report if you prefer. Contact information is provided below.

Thank you in advance for your time in completing this form and giving us your feedback. We value your input and greatly appreciate your efforts. Please send the completed form and comments to MetaWorks by May 12, 2000.

Contact: | Rhonda P. Estok, RN, BSN, CNOR, Metaworks Inc.
| Phone: (781) 395-0415 x254, Fax: (781) 395-7336, email: restok@metawork.com

Please print legibly or type comments here:

_________________________________________________________________________________________________

_________________________________________________________________________________________________

________________________________ (signature) | _______________ (date)
________________________________ (print name)