# Evidence Tables

## Evidence Table Acronyms

2x2's | data tables amenable to computations of sensitivity and specificity
AED | antiepileptic drug
CT | computed tomography
DAE | discontinuation due to adverse event
DNC | discontinuation due to noncompliance
Dx | diagnosis
ECT | electroconvulsive therapy
EEG | electroencephalogram
exp | expertise
GTC | generalized tonic clonic
ILAE | International League Against Epilepsy
LP | lumbar puncture
MRI | magnetic resonance imaging
neuropsych | neuropsychiatric
NPV | negative predictive value
NR | not reported
NS | not specified
OT | occupational therapy
PET | positron emission tomography
pharm | pharmacologic
PPV | positive predictive value
PT | physical therapy
QoL | quality of life
R | repeated
RCT | randomized controlled trial
Rx | treatment
soph | sophisticated
SPECT | single-photon emission computed tomography
std | standard
T0 | time zero
XS | cross-sectional

Evidence Table 1. Study Level Characteristics I (k^1^)

| Interventional | | | Observational
| Total | RCT | Others | Total | Prospective | Retrospective
Total | 70 | 31 | 39 | 50 | 17 | 33
Publication Year
1990-1999 | 53 | 25 | 28 | 36 | 17 | 19
1980-1989 | 17 | 6 | 11 | 14 | 0 | 14
Location
Europe | 46 | 26 | 20 | 28 | 12 | 16
North America | 17 | 6 | 11 | 14 | 4 | 10
Other | 10 | 1 | 9 | 8 | 1 | 7
Evidence Score (mean, range) | 1.2 (0.3-5.0) | 2.27 (0.5-5.0) | 0.3 (0.3-0.3) | 0.3 (0.3-0.3) | 0.3 (0.3-0.3) | 0.3 (0.3-0.3)
Study Duration
max (mos) | k=48 19.1 | k=29 24.0 | k=19 11.8 | k=29 81.4 | k=15 62.4 | k=14 101.9
mean/median (mos) | k=7 (0.1-44 m) | k=5 (30-44 m) | k=2 (0.1-44 m) | k=15 (14.7-120 m) | k=8 (14.7-86.4 m) | k=7 (15-120 m)
NR | k=10 | k=1 | k=9 | k=16 | k=1 | k=15
Classification system used
ILAE '81 | 19 | 12 | 7 | 15 | 12 | 3
ILAE '89 | 6 | 2 | 4 | 11 | 4 | 7
Other | 5 | 3 | 2 | 3 | 2 | 2
NR | 41 | 14 | 27 | 26 | 4 | 22
Industry sponsored | 25 | 23 | 2 | 1 | 0 | 1
Cost? Yes | 2 | 0 | 2 | 0 | 0 | 0
QoL? Yes | 2 | 2 | 0 | 1 | 0 | 1

1 k, unless others were specified. (k=number of studies)

Notes: 3 interventional studies were conducted in both North America and Europe. 1 interventional study reports both ILAE 1981 and 1989. 5 observational studies report both ILAE 1981 and 1989. 10 interventional studies and 3 observational studies reported duration as XS. 2 interventional studies and 2 observational studies reported duration as a range. These studies were included as reported, but not included in calculation of the mean study duration.

Evidence Table 2. Study Level Charactersitics II (k^1^)

| Interventional | | | Observational
| Total | RCT | Others | Total | Prospective | Retrospective
Intervention location | 70 | 31 | 39 | 50 | 17 | 33
Home | 1 | 0 | 1 | 0 | 0 | 0
Hospital | 41 | 20 | 21 | 35 | 10 | 25
Office/Clinic | 9 | 4 | 5 | 3 | 1 | 2
Epilepsy Center | 12 | 6 | 6 | 15 | 6 | 9
Academia | 40 | 13 | 27 | 34 | 12 | 22
Other | 2 | 0 | 2 | 2 | 1 | 1
NR/Unknown | 7 | 5 | 2 | 5 | 2 | 3
Usual epilepsy provider
Primary Care/Internist | 0 | 0 | 0 | 1 | 0 | 1
Neurologist | 2 | 0 | 2 | 3 | 2 | 1
Epilepsy Specialist | 0 | 0 | 0 | 0 | 0 | 0
Surgeon/Radiologist | 0 | 0 | 0 | 0 | 0 | 0
Other | 0 | 0 | 0 | 1 | 1 | 0
NR/Unknown | 68 | 31 | 37 | 15 | 15 | 0
Investigator
Single designations: | 30 | 15 | 15 | 23 | 3 | 20
Academician | 2 | 0 | 2 | 2 | 1 | 1
Epilepsy specialist | 2 | 1 | 1 | 0 | 0 | 0
Neurologist | 24 | 13 | 11 | 18 | 2 | 16
Primary care/internist | 0 | 0 | 0 | 0 | 0 | 0
Surgeon | 0 | 0 | 0 | 0 | 0 | 0
Radiologist | 0 | 0 | 0 | 0 | 0 | 0
Other | 2 | 1 | 1 | 3 | 0 | 3
Multiple designations: | 34 | 11 | 23 | 22 | 11 | 11
NR/unknown | 6 | 5 | 1 | 5 | 3 | 2
Population
Adult | 25 | 14 | 11 | 13 | 5 | 8
Pediatrics | 21 | 8 | 13 | 17 | 5 | 12
Both | 24 | 9 | 15 | 20 | 7 | 13
Studies with patients on study at:
1st seizure | 5 | 1 | 4 | 12 | 9 | 3
1st presentation | 7 | 0 | 7 | 7 | 2 | 5
1st diagnosis | 56 | 30 | 26 | 6 | 5 | 1
not first event, but T0 in
observation window | 2 | 0 | 2 | 24 | 1 | 23
NR | 0 | 0 | 0 | 0 | 0 | 0
Inclusion criteria
NS
Specified | 34 | 9 | 25 | 26 | 4 | 22
First in specified time period | 36 | 22 | 14 | 24 | 13 | 11
First in unspecified time period | k=1 | 0 | k=1 (1.5 mos) | k=1 | k=1 (0.03 mos) | 0
> 1 seizure in specified time period | 0 | 0 | 0 | k=1 | 0 | k=1
> 1 seizure in unspecified time period | k=4 | k=1 (0.25 mos) | k=3 (0.4-6 mos) | k=7 | k=5 (0.03-3 mos) | k=2 (6-36 mos)
> 2 seizure in specified time period | k=2 | 0 | k=2 | k=6 | k=5 | k=1
> 2 seizure in unspecified time period | k=17 | k=15 (2-36 mos) | k=2 (5-12 mos) | k=1 | 0 | k=1 (3 mos)
> 3 seizure in specified time period | k=7 | k=4 | k=3 | k=6 | k=2 | k=4
> 3 seizure in unspecified time period | k=1 | k=1 (6 mos) | 0 | k=1 | 0 | k=1 (6 mos)
> 4 seizure in specified time period | k=1 | 0 | k=1 | 0 | 0 | 0
> 4 seizure in unspecified time period | k=1 | k=1 (per day for 0.5 mos | 0 | 0 | 0 | 0
# Seizures NR for specified/unspecified time period | 0 | 0 | 0 | 0 | 0 | 0
Seizure Unprovoked (yes) | k=34 | k=9 | k=25 | k=27 | k=4 | k=23
Exclusion Criteria | 16 | 9 | 7 | 17 | 13 | 4
NS | 32 | 8 | 24 | 24 | 3 | 21
Specified | 38 | 23 | 15 | 26 | 14 | 12

1 k, unless otherwise specified (k=number of studies)

Notes:Intervention location: Multiple studies reported more than one of the choices for intervention location. Usual epilepsy provider: Multiple studies reported more than one of the choices for usual epilepsy provider. Seizures/time period: One interventional "Other" study reported <2 seizures in past 1 month (not included in above numbers).

Evidence Table 3. Patient Level Characterisitcs (k/n)

| Interventional | Observational
| k, n/N, % | k, n/N, %
Total Patients | k=70 n=8310 | k=50 n=12903
Age (mean, median) | 28.5 years | 23.1 years
Race (C/AA/H/A/Other %) | k=6 n=538 286/59/0/73/0 68.8%/14.1%/0%/17.6%/0% | k=3 n=1353 676/252/354/27/44 50.0%/18.6%/26.2%/2.0%/3.3%
Gender (M/F%) | k=60 M=4280/7555 (56.7%) k=60 F=3275/7555 (43.3%) | k=35 M=3051/5797 (52.6%) k=35 F=2746/5797 (47.4%)
Family history (%) | k=5 72/826 (8.7%) | k=15 311/1731 (18.0%)
% on AEDs at entry | k=50 136/6347 (2.1%) | k=18 353/1847 (19.1%)
% history of AED use | k=43 422/5130 (8.2%) | k=11 112/1115 (10.0%)
Epilepsy/Seizure Type/Incidence | k=52 n=5887 | k=39 n=6718
% generalized tonc clonic | k=35 1895/5887 (32.2%) | k=26 2911/6718 (43.3%)
% partial | k=23 1942/5887 (33.0%) | k=10 742/6718 (11.0%)
%partial simple | k=9 178/5887 (3.0%) | k=9 112/6718 (1.7%)
%partial simple, 2 generalized | k=12 681/5887 (11.6%) | k=9 767/6718 (11.4%)
%partial complex | k=21 524/5887 (8.9%) | k=13 380/6718 (5.7%)
%partial complex, 2 generalized | k=0 | k=3 39/6718 (0.6%)
%absence (petit mal) | k=15 193/5887 (3.3%) | k=10 129/6718 (1.9%)
%other/miscellaneous | k=16 212/5887 (3.6%) | k=27 1219/6718 (18.1%)
%NR | k=4 242/5887 (4.1%) | k=2 240/6718 (3.6%)

k = number of studies and n = number of patients for studies contributing data Notes: Gender reported for 163 fewer patients than enrolled on interventional studies. 1 interventional study reported 101 patients with "Simple partial/complex partial". 1 interventional study reported 89 patients with "Partial +/− secondary generalized". 1 observational study reported 9/63 with generalized and 59/63 with complex partial. 1 observational study reported 73 patients as "no diagnosis". 1 observational study reported 98 patients as "mixed". These 171 patients are not included in the above numbers.

Evidence Table 4. Outcomes: Diagnostic Interventions (Interventional) I

| Interventional Studies
| Who? | Diagnosis Made after? | Diagnosis changed after?
| k, n/N, % patients | k, n/N, % patients | k, n/N, % patients
History/Physical | k=24 2881/2881 (100%) | Yes, k=14 Yes, k=3 200/486 (41%) | No, k=6
Blood Tests | k=14 1787/1787 (100%) | Yes, k=4 Yes, k=1 167/167 | No, k=6
Neuropsychiatric Assessment | k=16 1489/1489 (100%) | Yes, k=8 | No, k=5
LP | k=1 42/42 (100%) | No, k=1 | No, k=1
CT | k=9 935/1279 (73.1%) | Yes, k=2 Yes, k=2 186/186 (100%) No, k=1 | No, k=3
EEG (standard) | k=35 4573/4582 (99.8%) | Yes, k=21 Yes, k=4 455/523 (86.9%) No, k=1 | Yes, k=1 No, k=6
MRI | k=7 527/622 (84.7%) | Yes, k=3 Yes, k=2 253/350 (72.3%) No, k=1 | Yes, k=1 No, k=1
PET/SPECT | k=0 | NR | NR
EEG (invasive) | k=0 | NR | NR
EEG (video) | k=4 152/152 (100%) | Yes, k=1 Yes, k=2 98/118 (83.1%) | No, k=1
EEG (ambulatory) | k=4 137/137 (100%) | Yes, k=2 | NR
EEG (other) | k=3 365/431 (84.7%) | Yes, k=2 Yes, k=1 123/123 | Yes, k=1 ^2^

k = number of studies contributing data. other values reported include number of patients (n)/number of total patients studied in k studies (N), and percent. studies reporting "Yes" or "No" for diagnosis made or changed but not reporting n/N are listed separately.

2 Study reported "yes" in 8 patients.

Evidence Table 4a. Outcomes: Diagnostic Interventions (Observational) I

| Observational Studies
| Who? | Diagnosis Made after? | Diagnosis changed after?
| k, n/N, % patients | k, n/N, % patients | k, n/N, % patients
History/Physical | k=32 8562/8562 (100%) | Yes, k=22 | Yes, k=3 76/161 (47.2%) No, k=3
Blood Tests | k=3 419/419 (100%) | Yes, k=2 | Yes, k=1
Neuropsychiatric Assessment | k=8 1284/1284 (100%) | Yes, k=4 | NR
LP | k=1 ^2^ 227/333 (68.2%) | Yes, k=1 | NR
CT | k=15 ^3^ 1875/2205 (85.1%) | Yes, k=10 | No, k=1
EEG (standard) | k=32 ^4^ 5103/5182 (98.5%) | Yes, k=16 | Yes, k=1 Yes, 81/172 (47.1%), k=4 No, k=2
MRI | k=7 ^5^ 279/776 (36.0%) | Yes, k=5 | NR
PET/SPECT | k=1 91/160 (56.9%) | NR | NR
EEG (invasive) | NR | NR | NR
EEG (video) | k=7 1234/1288 (95.8%) | Yes, k=3 Yes, 175/758 (23.1%), k=4 | Yes, k=1 Yes, 24/60 (40.0%), k=1
EEG (ambulatory) | k=1 20/20 (100%) | Yes, k=1 Yes, 3/20 (15.0%), k=1 | Yes, k=1
EEG (other) | NR | NR | NR

1 k = number of studies contributing data. Other values reported include number of patients (n)/number of total patients studied in k studies (N), and percent.

2 Value for k does not reflect one study (Forsgren, 1996) that reported "<100%" rather than actual numbers of patients.

3 Value for k does not reflect one study (Berg, 1999) that reported "<100%" rather than actual numbers of patients.

4 Value for k does not reflect one study (Luhdorf, 1986) that reported "<100%" rather than actual numbers of patients.

5 Value for k does not reflect three studies (Aikia, 1999; Arts, 1999; Berg, 1999) that reported "<100%" rather than actual numbers of patients.

Evidence Table 5. Outcomes: Diagnostic interventions (Interventional) II

| Interventional Studies
| Gold Std Used | Sensitivity | Specificity | "R" | PPV | NPV | 2x2's
History/Physical | k=7 735/735 (100%) | NR | NR | NR | NR | NR | NR
Blood Tests | k=4 373/373 (100%) | k=1 | NR | NR | k=1 | k=1 | k=1
Neuropsych | k=2 278/278 (100%) | NR | NR | NR | NR | NR | NR
LP | NR | NR | NR | NR | NR | NR | NR
CT | k=2 ^2^ 64/350 (18.3%) | NR | NR | NR | NR | NR | NR
EEG std | k=7 555/555 (100%) | NR | NR | NR | NR | NR | k=1
MRI | k=2 ^3^ 313/350 (89.4%) | NR | NR | NR | NR | NR | NR
PET/SPECT | NR | NR | NR | NR | NR | NR | NR
EEG invasive | NR | NR | NR | NR | NR | NR | NR
EEG video | NR | NR | NR | NR | NR | NR | NR
EEG ambulatory | k=1 45/45 (100%) | NR | NR | NR | NR | NR | NR
EEG other | k=1 45/45 (100%) | NR | NR | NR | NR | NR | NR

k and n/N contributing data -- for all fields that are "not null" -- and the % n refers to patient numerators, n and denominators, N. Notes:

2 CT - 4 studies, but only 2 report n/N.

3 MRI - 3 studies, but only 2 report n/N.

Evidence Table 5a. Outcomes: Diagnostic Interventions (Observational) II

| Observational Studies
| Gold Std Noted | Sensitivity | Specificity | "R" | PPV | NPV | 2x2's
History/Physical | k=9 1245/1245 (100%) | k=2 | k=2 | NR | NR | NR | NR
Blood Tests | k=1 165/165 (100%) | NR | NR | NR | NR | NR | NR
Neuropsych | k=1 165/165 (100%) | NR | NR | NR | NR | NR | NR
LP | NR | NR | NR | NR | NR | NR | NR
CT | k=2 438/438 (100%) | NR | NR | NR | NR | NR | k=1
EEG std | k=10 1468/1468 (100%) | NR | NR | NR | NR | NR | NR
MRI | k=1 273/273 (100) | NR | NR | NR | NR | NR | NR
PET/SPECT | NR | NR | NR | NR | NR | NR | NR
EEG invasive | NR | NR | NR | NR | NR | NR | NR
EEG video | k=1 60/60 (100%) | NR | NR | NR | NR | NR | NR
EEG ambulatory | NR | NR | NR | NR | NR | NR | NR
EEG other | NR | NR | NR | NR | NR | NR | NR

1 k and n/N contributing data -- for all fields that are "not null" -- and the % n refers to patients numerators, n and denominators, N.

Evidence Table 6. Outcomes: Monitoring Interventions (Interventional) I

| Interventional Studies
| WHO? | WHEN? | FREQUENCY?
| k, n/N, % Patients
Pharm Expertise | k=1 k=15 3214/3214 100% | k=14 variable | k=14 variable
Blood tests | k=1 k=22 2322/2328 99.7% | k=21 variable | k=19 variable
Drug levels (std) | k=2 k=36 4280/4309 99.3% | k=30 variable | k=24 variable
Drug levels (soph) | k=1 k=3 311/311 100% | k=2 variable | k=2
EEG std | k=1 k=10 645/645 100% | k=10 variable | k=8 variable
EEG invasive | k=0 | k=0 | k=0
EEG video | k=2 28/28 100% | k=2 variable | k=2 variable
EEG ambulatory | k=1 k=2 55/55 100% | k=3 variable | k=2 variable

1 k and n/N contributing data -- for all fields that are "not null" -- and the % n refers to patient numerators, n and denominators, N.

Studies reporting WHO but not reporting n/N are listed separately.

Note: Other interventions k=15 studies reported "other" monitoring interventions. "OTHER" monitoring interventions reported: Clinical exam, visual evoked potentials, QoL, neuropsych tests, psychomotor function tests, multiple sleep latency tests k=7 neuropsych tests. Total number of interventional studies: k=70. Number of interventional studies contributing data: k=52.

Evidence Table 6a. Outcomes: Monitoring Interventions (Observational) I

| Observational Studies
| WHO? | When? | Frequency?
Pharm Expertise | k=4 1315/1315 100% | k=3 Throughout study | k=3 variable
Blood tests | k=1 78/78 100% | k=1 Throughout study | k=0
Drug levels (std) | k=3 k=5 112/197 56.9% | k=3 variable | k=1 "periodically"
Drug levels (soph) | k=0 | k=0 | k=0
EEG std | k=2 k=4 555/555 100% | k=4 variable | k=4 variable
EEG invasive | k=0 | k=0 | k=0
EEG video | k=1 92/92 100% | k=1 @ entry | k=1 once
EEG ambulatory | k=0 | k=0 | k=0

1 k and n/N contributing data -- for all fields that are "not null -- and the % n refers to patient numerators, n and denominators, N.

Studies reporting WHO but not reporting n/N are listed separately.

Note: Other interventions: k=2 studies reporting "other" monitoring interventions. "OTHER" monitoring interventions reported: neuropsych tests, and endocranial ECT. Total number of observational studies: k=50. Number of observational studies contributing data: k=16.

Evidence Table 7. Monitoring Interventions (Interventional) II

Change In: | Interventional Studies
Change In: | Seizure Freedom After | DAEs After | DNCs After | QoL change After | Changed Dx After | Changed Rx After
Pharm Expertise | NR | NR | NR | NR | NR | k=1 249/622 (40%)
Blood tests | NR | k=1 2/10 (20%) ^2^ | NR | NR | NR | NR
Drug levels (standard) | NR | NR | NR | NR | NR | k=1 35/181 (19.3%)
Drug levels (sophisticated) | NR | NR | NR | NR | NR | NR
EEG standard | NR | NR | NR | NR | NR | NR
EEG invasive | NR | NR | NR | NR | NR | NR
EEG video | NR | NR | NR | NR | NR | NR
EEG ambulatory | NR | NR | NR | NR | NR | NR

1 k = number of studies contributing data. Other values reported include number of patients (n)/number of total patients studied in k studies (N), and percent.

2 Change was an increase in adverse events for the 2 patients having blood tests done (Stefan, 1988).

Evidence Table 7a. Outcomes: Monitoring Interventions (Observational) II

Change In: | Observational Studies
Change In: | Seizure Freedom After | DAEs After | DNCs After | QoL change After | Changed Dx After | Changed Rx After
Pharm Expertise | NR | NR | NR | NR | NR | NR
Blood tests | NR | NR | NR | NR | NR | NR
Drug levels (standard) | NR | NR | NR | NR | NR | NR
Drug levels (sophisticated) | NR | NR | NR | NR | NR | NR
EEG (standard) | NR | NR | NR | NR | NR | NR
EEG (invasive) | NR | NR | NR | NR | NR | NR
EEG (video) | NR | NR | NR | NR | k=1 60/68 (88%)2 | k=1 86/192 (45%)
EEG (ambulatory) | NR | NR | NR | NR | NR | NR

1 k = number of studies contributing data. Other values reported include number of patients (n)/number of total patients studied in k studies (N), and percent.

2 Chen (1985) reported that 60/68 patients referred for seizure classification were successfully classified.

Evidence Table 8. Outcomes: Treatment Interventions (Interventional) I

| WHO | How Long? | Seizure Free at | | | | | | Remission Rate at | | | | | Recurrence Rate at
| n/N (%) k | mean (yrs) range, k | NR | 0.5 year | 1 year | 2 years | 3 years | 5 years | NR | 1 year | 2 years | 3 years | 5 years | NR | 1 year | 2 years | 3 years | 5 years
No Rx | 337/680 (49.6%) k=3 | 2 wks - > 2 yrs | NR | NR | NR | NR | NR | NR | NR | NR | 122/204 (59.8%) k=1 | NR | NR | 85/204 (41.7%) k=1 | NR | NR | NR | NR
Drug studies | 996/996(100%) k=4 | >5 wks - < 6 yrs | NR | NR | NR | NR | NR | NR | 594/667 (89.0%) k=2 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Drug Rx: Mono | 5897/6479 (91.0%) k=49 | 2 wks - < 6 yrs | 430/1037 (41.4%) k=8 | 243/496 (49.0%) k=2 | 648/1028 (63.0%) k=6 | 382/636 (60.1%) k=3 | 12/43 (27.9%) k=1 | NR | 781/1048 (74.5%) k=8 | NR | NR | NR | NR | 247/501 (49.3%) k=5 | NR | NR | NR | NR
Drug Rx: Poly | 122/622 (19.6%) k=1 | < 6 years | NR | NR | NR | NR | NR | NR | 55/122 (45.1%) k=1 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pharm Exp. | 72/72 (100%) k=2 | 2 mos - < 6 yrs | NR | NR | NR | NR | NR | NR | 76/91 (83.5%) k=3 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Social services | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Counsel | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Speech | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
OT/PT | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Education | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Surgery | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Other | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 n refers to patient numerators -n- and denominators -N.

Decreased seizure frequency=remission.

Evidence Table 8a. Outcomes: Treatment Interventions (Observational) I^1^

| WHO | How Long? | Seizure Free at | | | | | Remission Rate at | | | | | Recurrence Rate at
| n/N (%) k | mean (yrs) range, k | 0.5 year | 1 year | 2 years | 3 years | 5 years | 0.5 year | 1 year | 2 years | 3 years | 5 years | 0.5 year | 1 year | 2 years | 3 years | 5 years
No Rx | 954/2172 (43.9%) k=12 | < 2 yr - < 5.8 yr k=4 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | 71/207 (34.3%) k=2 | 184/483 (38.0%) k=2 | 130/350 (37.1%) k=1 | 94/133 (70.7%) k=1 | 147/350 (42.0%) k=1
Drug studies | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Drug Rx: Mono | 2161/2624 (82.4%) k=14 | > 1 yr - mean 5.8 yr k=7 | NR | 60/64 (93.8%) k=2 | NR | 196/640 (30.6%) k=1 | NR | NR | NR | NR | NR | NR | 153/454 (33.7%) k=2 | 25/62 (40.3%) k=1 | NR | 26/62 (41.9%) k=1 | 28/62 (45.2%) k=1
Drug Rx: Poly | 111/773 (14.4%) k=7 | 6.8-10.4 yrs mean k=1 | NR | 3/6 (50%) k=1 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pharm Exp. | 4744/4902 (96.8%) K=10 | > 1 year - 15 yrs k=2 | NR | NR | NR | 599/730 (82.1%) k=1 | NR | NR | NR | NR | NR | NR | 61/168 (36.3%) k=1 | 7/23 (30.4%) k=1 | NR | NR | NR
Social services | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Counsel | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Speech | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
OT/PT | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Education | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Surgery | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Other | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 k and n/N contributing data -- for all fields that are "not null" -- and the %

2 includes 79/89 "decreased seizures" and 346/417 "controlled".

Collaborative group: 218 patients achieved 1-year remission 189 patients achieved 2-year remission. 143 patients achieved 3-year remission ion.

Evidence Table 9. Outcomes: Treatment Interventions (Interventional) II^1^

| DAEs | | | DNC | | | QoL change
| k | n/N | % | k | n/N | % | k | n/N | %
No Rx | 1 | 0/18 | 0 | NR | NR | NR | NR | NR | NR
Drug studies | 1 | 17/45 | 37.8 | NR | NR | NR | NR | NR | NR
Drug Rx: Mono | 16 | 413/2837 | 14.6 | 8 | 127/1813 | 7 | NR | NR | NR
Drug Rx: Poly | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pharm Exp. | 1 | 1/51 | 2 | NR | NR | NR | NR | NR | NR
Social services | NR | NR | NR | NR | NR | NR | NR | NR | NR
Counsel | NR | NR | NR | NR | NR | NR | NR | NR | NR
Speech | NR | NR | NR | NR | NR | NR | NR | NR | NR
OT/PT | NR | NR | NR | NR | NR | NR | NR | NR | NR
Education | NR | NR | NR | NR | NR | NR | NR | NR | NR
Surgery | NR | NR | NR | NR | NR | NR | NR | NR | NR
Other | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 k and n/N contributing data -- for all fields that are "not null" -- and the % n refers to patient numerators, N.

Evidence Table 9a. Outcomes: Treatment Interventions (Observational) II^1^

| DAEs | | | DNC | | | QoL change
| k | n/N | % | k | n/N | % | k | n/N | %
no Rx | NR | NR | NR | NR | NR | NR | NR | NR | NR
Drug studies | NR | NR | NR | NR | NR | NR | NR | NR | NR
Drug Rx: Mono | NR | NR | NR | NR | NR | NR | NR | NR | NR
Drug Rx: Poly | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pharm Exp. | NR | NR | NR | NR | NR | NR | NR | NR | NR
Social services | NR | NR | NR | NR | NR | NR | NR | NR | NR
Counsel | NR | NR | NR | NR | NR | NR | NR | NR | NR
Speech | NR | NR | NR | NR | NR | NR | NR | NR | NR
OT/PT | NR | NR | NR | NR | NR | NR | NR | NR | NR
Education | NR | NR | NR | NR | NR | NR | NR | NR | NR
Surgery | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 k and n/N contributing data -- for all fields that are "not null" -- and the % n refers to patients numerators, n denominators, N.

Evidence Table 10. Treatment Interventions: Optimal Outcomes Defined (Interventional)^1^

| 0 in: | | | | 1 in: | | | | 2 in: | | | | 3 in:
| < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos
Seizures^2^ | 4 | 3 | 15 | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
Side Effects^3^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Compliance^4^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
QoL^5^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Costs^6^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 k, unless otherwise specified (k=number of studies)

2 Number of studies where optimal outcomes defined using seizures.

3 Number of studies where optimal outcomes defined using side effects.

4 Number of studies where optimal outcomes defined using compliance.

5 Number of studies where optimal outcomes defined using QoL.

6 Number of studies where optimal outcomes defined using costs.

Evidence Table 10a. Treatment Interventions: Optimal Outcomes Defined (Observational)^1^

| 0 in: | | | | 1 in: | | | | 2 in: | | | | 3 in:
| < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos | < 3 mos | < 6 mos | < 12 mos | < 24 mos
Seizures^2^ | 2 | NR | 8 | 5 | NR | NR | | NR | NR | NR | NR | NR | NR | NR | NR | NR
Side Effects^3^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Compliance^4^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
QoL^5^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Costs^6^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

1 k, unless otherwise specified (k=number of studies)

2 Number of studies where optimal outcomes defined using seizures.

3 Number of studies where optimal outcomes defined using side effects.

4 Number of studies where optimal outcomes defined using compliance.

5 Number of studies where optimal outcomes defined using QoL.

6 Number of studies where optimal outcomes defined using costs.

Table 11. Studies Reporting Significant Prognostic Factors for Seizure Recurrence

| | | Covariates as Significant Predictors of Seizure Recurrence
Author/Year | Number of Patients | Adult/Pediatric/Both | Seizure Type | Maximum Follow-up Time (mos) | Age | Remote Symptoms | Seizure Type | EEG | Neuropsychiatric Impairment | Type of AED | Etiology | Other
Bora 1995 | 147 | Adult | all GTC | 54 | | | | | | | | Time of day of first seizure
Hauser 1998 | 204 | Both | Mixed | 100 | | | Risk after #1,2,3 seizures
Hauser 1990 | 208 | Both | NR | 48 | | Y | | Y | | N | | Positive family history
Shinnar 1996 | 407 | Both | NR | 130 | | Y | | | | No difference if not treated
Camfield 1985(a) | 168 | Pediatric | Mixed | 54 | | Y (febrile seizures) | Y | Y | Y | No difference if not treated | | No difference if sleep or wake seizures
Camfield 1985(b) | 82 | Pediatric | Mixed | 36 | | | Y (type and #) | | | N
Aikia 1999 | 89 | Adult | all partial | 24 | Y | Y | Y | | Y
Anzola 1993 | 59 | Both | NR | | | | | | | | | Prolactin
Arts 1999 | 466 | Pediatric | Mixed | 24 | | | Y
Camfield 1997 | 417 | Pediatric | Mixed | 92 (mean) | | | Y | | Y | Y
Casetta 1999 | 128 | Pediatric | Mixed | NR | Y | | Y | N | N | N | Y
Van Paesschen 1997 | 63 | Adult | all partial | NR | | | | | | | | MRI
Cockerell 1997 | 792 | Both | Mixed | 108 | Y | | Y
Holt-Seizt 1999 | 84 | Adult | Mixed | 159 | | | Y (#) | Y | | Y (if AED stopped)
Luhdorf 1986 | 97 | Adult | Mixed | >= 1 | | | N | Y | | Y (drug levels) | N

Mixed = generalized and partial.

## References

Aikia M, Kalviainen R, Mervaala E, et al Predictors of seizure outcome in newly diagnosed partial epilepsy: Memory performance as a prognostic factor Epilepsy Res 1999 37(2):159 167 10510982
Aikia M, Kalviainen R, Riekkinen PJ Verbal learning and memory in newly diagnosed partial epilepsy Epilepsy Res 1995 22(2):157 164 8777902
Aikia M, Kalviainen R, Sivenius J, et al Cognitive effects of oxcarbazepine and phenytoin monotherapy in newly diagnosed epilepsy: One year follow-up Epilepsy Res 1992 11(3):199 203 1396535
Altunbasak S, Biatmakoui F, Baytok V, et al Serum and hair zinc levels in epileptic children taking valproic acid Biol Trace Elem Res 1997 58(1-2):117 125 9363326
Ambrosetto G, Giovanardi RP, Tassinari CA Predictive factors of seizure frequency and duration of antiepileptic treatment in rolandic epilepsy: A retrospective study Brain Dev 1987 9(3):300 4 3661910
Andrewes DG, Bullen JG, Tomlinson L, et al A comparative study of the cognitive effects of phenytoin and carbamazepine in new referrals with epilepsy Epilepsia 1986 27(2):128 134 3956451
Anzola GP Predictivity of plasma prolactin levels in differentiating epilepsy from pseudoseizures: A prospective study Epilepsia 1993 34(6):1044 8 8243355
Arteaga R, Herranz JL, Armijo JA Platelet GABA-transaminase in epileptic children: Influence of epilepsy and anticonvulsants Epilepsy Res 1993 14(1):73 85 8449181
Arts WF, Geerts AT, Brouwer OF, et al The early prognosis of epilepsy in childhood: The prediction of a poor outcome. The Dutch study of epilepsy in childhood Epilepsia 1999 40(6):726 34 10368070
Atakli D, Sozuer D, Atay T, et al Misdiagnosis and treatment in juvenile myoclonic epilepsy Seizure 1998 7(1):63 6 9548228
Austin J, Dunn D, Huster G, et al Development of scales to measure psychosocial care needs of children with seizures and their parents J Neurosci Nurs 1998 30(3):155 60 9689606
Austin JK. Concerns and fears of children with seizures. Clin Nurs Practice Epilepsy. 1993;1:4-6.
Baker GA, Nashef L, van Hout BA Current issues in the management of epilepsy: The impact of frequent seizures on cost of illness, quality of life, and mortality Epilepsia 1997 38(Suppl 1):1 8
Bawden HN, Camfield CS, Camfield PR, et al The cognitive and behavioural effects of clobazam and standard monotherapy are comparable Epilepsy Res 1999 33(2-3):133 43 10094425
Bawden HN, Camfield CS, Camfield PR, et al. The cognitive and behavioral effects of clobazam and standard monotherapy are comparable. Canadian Study Group for Childhood Epilepsy. Epilepsy Res. 1999;33:133-43. [pmid: 10094425].
Beghi E, Tognoni G Prognosis of epilepsy in newly referred patients: A multicenter prospective study Collaborative Group for the Study of Epilepsy Epilepsia 1988 29(3):236 43
Begley CE, Famulari M, Annegers JF, et al The cost of epilepsy in the United States: An estimate from population-based clinical and summary data Epilepsia 2000 41(3):342 51 10714408
Beilmann A, Napa A, Soot A, et al Prevalence of childhood epilepsy in Estonia Epilepsia 1999 40(7):1011 9 10403228
Berg AT, Shinnar S, Levy SR, et al Newly diagnosed epilepsy in children: Presentation at diagnosis Epilepsia 1999a 40(4):445 52 10219270
Berg AT, Shinnar S, Levy SR, et al Status epilepticus in children with newly diagnosed epilepsy Ann Neurol 1999b 45(5):618 23 10319884
Berg I, Butler A, Ellis M, et al Psychiatric aspects of epilepsy in childhood treated with carbamazepine, phenytoin or sodium valproate: A random trial Dev Med Child Neurol 1993 35(2):149 57 8444328
Bill PA, Vigonius U, Pohlmann H, et al. A double-blind controlled clinical trial of oxcarbazepine versus phenytoin in adults with previously untreated epilepsy. Epilepsy Res. 1997;27:195-204. [pmid: 9237054].
Bora I, Seckin B, Zarifoglu M, et al Risk of recurrence after first unprovoked tonic-clonic seizure in adults J Neurol 1995 242(3):157 63 7751859
Borah NC, Matheshwari MC Effect of antiepileptic drugs on short-latency somatosensory evoked potentials Acta Neurol Scand 1985 71(4):331 3 4003038
Braathen G, Theorell K A general hospital population of childhood epilepsy Acta Paediatri 1995 84(10):1143 6
Brodie MJ, Richens A, Yuen AW Double-blind comparison of lamotrigine and carbamazepine in newly diagnosed epilepsy. UK Lamotrigine/Carbamazepine Monotherapy Trial Group Lancet 1995 345(8948):476 9 7710545
Brouwer OF, van Donselaar CA, Stroink H, et al The Dutch study of epilepsy in childhood: Design of the study Epilepsia 1995 36Suppl 3:
Buckner FS, Eschbach JW, Haley NR, et al Hypertension following erythropoietin therapy in anemic hemodialysis patients Am J Hypertens 1990 3(12):947 55 2127895
Bye A, Lamont P, Healy L. Commencement of a pediatric EEG-video telemetry service. Clin Exp Neurol. 1990;27:83-88. [pmid: 2129962].
Callaghan N, Garrett A, Goggin T Withdrawal of anticonvulsant drugs in patients free of seizures for two years. A prospective study N Engl J Med 1988 318(15):942 6 3127710
Callaghan N, Kenny RA, O'Neill B, et al. A prospective study between carbamazepine, phenytoin and sodium valproate asmonotherapy in previously untreated and recently diagnosed patients with epilepsy. J Neurol Neurosurg Psychiatry. 1985;48:639-44. [pmid: 3928820].
Camfield PR, Camfield CS, Dooley JM, et al Epilepsy after a first unprovoked seizure in childhood Neurolgy 1985a 35(11):1657 60
Camfield PR, Camfield CS, Smith EC, et al Newly treated childhood epilepsy: A prospective study of recurrences and side effects Neurology 1985b 35(5):722 5 3990971
Camfield PR, Camfield CS, Gordon K, et al If a first antiepileptic drug fails to control a child's epilepsy, what are the chances of success with the next drug? J Pediatr 1997 131(6):821 4 9427884
Clobazam has equivalent efficacy to carbamazepine and phenytoin as monotherapy for childhood eplepsy Epilepsia 1998 39(9):952 9 9738674
Caplan L, editor. Should single epileptic seizures be treated?. Eur Neurol. 1994;34:186-92. [pmid: 8082676].
Carenini L, Bottacchi E, Camerlingo M, et al Carbamazepine does not affect short-latency somatosensory evoked potentials: A longitudinal study in newly diagnosed epilepsy Epilepsia 1988 29(2):145 8 3349965
Carpay HA, Arts WF, Geerts AT, et al Epilepsy in childhood: An audit of clinical practice Arch Neurol 1998 55(5):668 73 9605723
Carpay JA, de Weerd AW, Schimsheimer RJ, et al The diagnostic yield of a second EEG after partial sleep deprivation: A prospective study in children with newly diagnosed seizures Epilepsia 1997 38(5):595 9 9184606
Casetta I, Granieri E, Monetti VC, et al Early predictors of intractability in childhood epilepsy: A community-based case-control study in Copparo, Italy Acta Neurol 1999 99(6):329 33
Chadwick D Safety and efficacy of vigabatrin and carbamazepine in newly diagnosed epilepsy: A multicenter randomised double-blind study. Vigabatrin European Monotherapy Study Group Lancet 1999 354(9172):13 9 10406359
Chadwick DW, Anhut H, Greiner MJ, et al A double-blind trial of gabapentin monotherapy for newly diagnosed partial seizures. International Gabapentin Monotherapy Study Group Neurology 1998 51(5):1282 8 9818846
Chandra B First seizure in adults: To treat or not to treat? Clin Neurol Neurosurg 1992 94(Suppl):S61 S63 1320521
Chen LS, Mitchell WG, Horton EJ, et al Clinical utility of video-EEG monitoring Pediatr Neurol 1995 12(3):220 4 7619188
Chen YJ, Kang WM, So WC Comparison of antiepileptic drugs on cognitive function in newly diagnosed epileptic children: A psychometric and neurophysiological study Epilepsia 1996 37(1):81 6 8603630
Christe W, Kramer G, Vigonius U, et al A double-blind controlled clinical trial: Oxcarbazepine versus sodium valproate in adults with newly diagnosed epilepsy Epilepsy Res 1997 26(3):451 60 9127726
Chu NS Long-term ambulatory cassette EEG with sphenoidal recording in complex partial seizures Epilepsia 1991 32(3):351 357 2044498
Cockerell OC, Johnson AL, Sander JW, et al Mortality from epilepsy: Results from a prospective population-based study Lancet 1994 344(8927):918 21 7934347
Cockerell OC, Johnson AL, Sander JWAS, et al. Remission of epilepsy: Results from the National General Practice Study of Epilepsy. Lancet. 1995;346:140-4. [pmid: 7603228].
Cockerell OC, Johnson AL, Sander JW, et al Prognosis of epilepsy: A review and further analysis of the first nine years of the British National General Practice Study of Epilepsy, a prospective population-based study Epilepsia 1997 38(1):31 46 9024182
Prognosis of epilepsy in newly referred patients: A multicenter prospective study of the effects of monotherapy on the long-term course of epilepsy Epilepsia 1992 33(1):45 51 1733759
Cook DJ, Guyatt GH, Laupacis A, et al. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest. 1992;102:305-11.
Cramer JA, Smith DB, Mattson RH, et al A method of quantification for the evaluation of antiepileptic drug therapy. The VA Epilepsy Cooperative Study Group Neurology 1983 33(Suppl 1):26 37 6681889
Crawford PM, Belchetz P, Davis C, et al Growth hormone response to diazepam, clonidine and glucagon in patients with epilepsy Epilepsy Res 1989 3(1):63 9 2492934
Cull RE An assessment of 24-hour ambulatory EEG/ECG monitoring in a neurology clinic J Neurol Neurosurg Psychiatry 1985 48(2):107 10 3981167
Dam AM, Fuglsang-Frederiksen A, Svarre-Olsen U, et al Late-onset epilepsy: Etiologies, types of seizure, and value of clinical investigation, EEG, and computerized tomography scan Epilepsia 1985 26(3):227 31 4006882
Dam M, Ekberg R, Loyning Y, et al A double-blind study comparing oxcarbazepine and carbamazepine in patients with newly diagnosed, previously untreated epilepsy Epilepsy Res 1989 3(1):70 6 2645120
Davidson DL, Ward NI Abnormal aluminium, cobalt, manganese, strontium and zinc concentrations in untreated epilepsy Epilepsy Res 1988 2(5):323 30 3197701
De Deyn PP, Mol L, de Ridder-Vanderdeelen P, et al An open multicentre prospective study of the effects of monotherapy with controlled-release carbamazepine on newly diagnosed generalized tonic-clonic seizures Seizure 1994 3(3):235 8 8000719
de Silva M, MacArdle B, McGowan M, et al Randomized comparative monotherapy trial of phenobarbitone, phenytoin, carbamazepine, or sodium valproate for newly diagnosed childhood epilepsy Lancet 1996 347(9003):709 13 8601999
Devinsky O, Vickrey BG, Cramer J, et al Development of the quality of life in epilepsy inventory Epilepsia 1995 36(11):1089 104 7588453
Di Mascio R, Beghi E, Sasaneilli F, et al. and the Collaborative Group for Epidemiology of Epilepsy. Early prognosis of epilepsy. Effects of treatment in the first follow-up year. Ital J Neurol Sci. 1986;7:421-9. [pmid: 3759415].
Drake MEJ, Weate SJ, Newell SA, et al Multiple sleep latency tests in epilepsy Clin Electroencephalogr 1994 25(2):59 62 8194189
Duchowny MS, Resnick TJ, Deray MJ, et al Video EEG diagnosis of repetitive behavior in early childhood and its relationship to seizures Pediatr Neurol 1988 4(3):162 4 3149479
Ehrhardt P, Forsythe WI Prognosis after grand mal seizures: A study of 187 children with three-year remissions Dev Med Child Neurol 1989 31(5):633 9 2509265
Elwes RD, Chesterman P, Reynolds EH Prognosis after first untreated tonic-clonic seizure Lancet 1985(8458):752 3
Ferrarese C, Tortorella R, Bogliun G, et al Decreased density of lymphocyte benzodiazepine receptors in drug-resistant epileptic patients Epilepsy Res 1997 27(3):181 5 9237052
Foley CM, Legido A, Miles DK, et al Diagnostic value of pediatric outpatient video-EEG Pediatr Neurol 1995 12(2):120 4 7779208
Forsgren L Prospective incidence study and clinical characterization of seizures in newly referred adults Epilepsia 1990 31(3):292 301 2344846
Forsgren L, Bucht G, Eriksson S, et al Incidence and clinical characterization of unprovoked seizures in adults: A prospective population-based study Epilepsia 1996 37(3):224 9 8598179
Forsythe I, Butler R, Berg I, et al Cognitive impairment in new cases of epilepsy randomly assigned to carbamazepine, phenytoin and sodium valproate Dev Med Child Neurol 1991 33(6):524 34 1864478
Frank LM, Enlow T, Holmes GL, et al Lamictal (lamotrigine) monotherapy for typical absence seizures in children Epilepsia 1999 40(7):973 9 10403222
Frost JDJ, Hrachovy RA, Glaze DG, et al Alpha rhythm slowing during initiation of carbamazepine therapy: Implications for future cognitive performance J Clin Neurophysiol 1995 12(1):57 63 7896910
Gastaut H, Aguglia U, Tinuper P Benign versive or circling epilepsy with bilateral 3-CPS spike-and-wave discharges in late childhood Ann Neurol 1986 19(3):301 3 3963776
Gelisse P, Genton P, Bureau M, et al Are there generalised spike waves and typical absences in benign rolandic epilepsy? Brain Dev 1999 21(6):390 6 10487473
Gilhus NE, Matre R Carbamazepine effects on mononuclear blood cells in epileptic patients Acta Neurol Scand 1986 74(3):181 5 3491486
Gobbi G, Pini A, Bertani G, et al Prospective study of first-line vigabatrin monotherapy in childhood partial epilepsies Epilepsy Res 1999 35(1):29 37 10232792
Grabow JD Complementary roles of EEG and CT Postgrad Med 1985 77(4):207 22 3919377
Granieri E, Rosati G, Tola R, et al. A descriptive study of epilepsy in the district of Copparo, Italy, 1964-1978. Epilepsia. 1983;24:502-14. [pmid: 6873007].
Grunewald RA, Chroni E, Panayiotopoulos CP Delayed diagnosis of juvenile myoclonic epilepsy J Neurol Neurosurg Psychiatry 1992 55(6):497 9 1619419
Gunduz E, Demirbilek V, Korkmaz B Benign rolandic epilepsy: Neuropsychological findings Seizure 1999 8(4):246 9 10452925
Hart YM, Sander JWAS, Shorvon SD. National General Practice Study of Epilepsy and Epileptic Seizures: Objectives and study methodology of the largest reported prospective cohort study of epilepsy. Neuroepidemiology. 1989;8:221-7. [pmid: 2812180].
Hart YM, Sander JWAS, Johnson AL, et al. National General Practice Study of Epilepsy: Recurrence after a first seizure. Lancet. 1990;336:1271-4. [pmid: 1978114].
Harvey AS, Berkovic SF, Wrennall JA, et al Temporal lobe epilepsy in childhood: Clinical, EEG, and neuroimaging findings and syndrome classification in a cohort with new-onset seizures Neurology 1997 49(4):960 8 9339674
Hauser WA, Anderson VE, Loewenson RB, et al. Seizure recurrence after a first unprovoked seizure. N Engl J Med. 1982;307:522-8. [pmid: 7099224].
Hauser WA, Rich SS, Annegers JF, et al. Seizure recurrence after a first unprovoked seizure: An extended follow-up. Neurology. 1990;40:1163-70. [pmid: 2381523].
Hauser WA, Rich SS, Lee JR, et al Risk of recurrent seizures after two unprovoked seizures N Engl J Med 1998 338(7):429 34 9459646
Living well with epilepsy: Report of the 1997 National Conference on Public Health and Epilepsy. CDC and NCCDPHP. 1998.
Heller AJ, Chesterman P, Elwes RD, et al Phenobarbitone, phenytoin, carbamazepine, or sodium valproate for newly diagnosed adult epilepsy: A randomised comparative monotherapy trial J Neurol Neurosurg Psychiatry 1995 58(1):44 50 7823066
Henneman PL, DeRoos F, Lewis RJ Determining the need for admission in patients with new-onset seizures Ann Emerg Med 1994 24(6):1108 4 7978592
Hoefnagels WA, Padb1erg GW, Overweg J, et al Transient loss of consciousness: The value of the history for distinguishing seizure from syncope J Neurol 1991 238(1):39 43 2030371
Holt-Seitz A, Wirrell EC, Sundaram MB Seizures in the elderly: Etiology and prognosis Can J Neuro Sci 1999 26(2):110 4
Hopkins A, Garmon A, Clarke C The first seizure in adult life Lancet 1988 1(8588):721 6 2895259
Hughes JR, Gruener G The success of EEG in confirming epilepsy -- Revisited Clin Electroencephalogr 1985 16(2):98 103 4006231
Isojarvi JI, Airaksinen KE, Mustonen JN, et al Thyroid and myocardial function after replacement of carbamazepine by oxcarbazepine Epilepsia 1995 36(8):810 6 7635100
Isojarvi JI, Pakarinen AJ, Myllyla VV. Serum lipid levels during carbamazepine medication. Arch Neurol. 1993;50:590-3. [pmid: 8099275].
Isojarvi JI, Pakarinen AJ, Myllyla VV. Basic hematological parameters, serum gamma-glutamyl-transferase activity, and erythrocyte folate and serum vitamin B12 levels during carbamazepine and oxcarbazepine therapy. Seizure. 1997;6:207-11. [pmid: 9203249].
Isojarvi JI, Pakarinen AJ, Myllyla VV. Thyroid function in epileptic patients treated with carbamazepine. Arch Neurol. 1989;46:1175-8. [pmid: 2510703].
Jadad AR, Moore A, Carroll D, et al. Assessing the quality of reports of randomized controlled trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jallon P, Goumaz M, Haenggeli C, et al Incidence of first epileptic seizures in the canton of Geneva, Switzerland Epilepsia 1997 38(5):547 52 9184600
Kalviainen R, Aikia M, Helkala EL, et al Memory and attention in newly diagnosed epileptic seizure disorder Seizure 1992 1(4):255 62 1344774
Kalviainen R, Aikia M, Saukkonen AM, et al Vigabatrin vs carbamazepine monotherapy in patients with newly diagnosed epilepsy. A randomized, controlled study Arch Neurol 1995 52(10):989 96 7575227
Kalviainen R, Halonen T, Pitkanen A, et al Amino acid levels in the cerebrospinal fluid of newly diagnosed epileptic patients: Effect of vigabatrin and carbamazepine monotherapies J Neurochem 1993 60(4):1244 50 8095971
Kalviainen R, Partanen K, Aikia M, et al MRI-based hippocampal volumetry and T2 relaxometry: Correlation to verbal memory performance in newly diagnosed epilepsy patients with left-sided temporal lobe focus Neurology 1997 48(1):286 7 9008539
Keranen T, Riekkinen PJ Remission of seizures in untreated epilepsy Br Med J 1993 307(6902):
Kilpatrick CJ, Tress BM, O'Donnell C, et al Magnetic resonance imaging and late-onset epilepsy Epilepsia 1991 32(3):358 64 1904345
King MA, Newton MR, Berkovic SF Benign partial seizures of adolescence Epilepsia 1999 40(9):1244 7 10487187
King MA, Newton MR, Jackson GD, et al Epileptology of the first-seizure presentation: A clinical, electroencephalographic, and magnetic resonance imaging study of 300 consecutive patients Lancet 1998 352(9133):1007 11 9759742
Kline Leidy N, Rentz AM, Grace EM Evaluating health-related quality of life outcomes in clinical trials of antiepileptic drug therapy Epilepsia 1998 39(9):965 77 9738676
Konishi T, Naganuma Y, Hongou K, et al Effects of antiepileptic drugs on EEG background activity in children with epilepsy: Initial phase of therapy Clin Electroencephalogr 1995 26(2):113 119 7781190
Kun LN, Ling LW, Wah YW, et al Epidemiologic study of epilepsy in young Singaporean men Epilepsia 1999 40(10):1384 7 10528933
Larkin JG, McKee PJ, Brodie MJ Rapid tolerance to acute psychomotor impairment with carbamazepine in epileptic patients Br J Clin Pharmacol 1992 33(1):111 4 1540481
Lee SI Nonconvulsive status epilepticus. Ictal confusion in later life Arch Neurol 1985 42(8):778 81 4026612
Luhdorf K, Jensen LK, Plesner AM Epilepsy in the elderly: Prognosis Acta Neurol Scand 1986 74(5):409 15 3825499
Mandelbaum DE, Burack GD The effect of seizure type and medication on cognitive and behavioral functioning in children with idiopathic epilepsy Dev Med Child Neurol 1997 39(11):731 5 9393886
Marciani MG, Maschio MC, Spanedda F, et al Sodium valproate and mental processes in newly referred epileptic patients. A computerized EEG study Neuropsychobiology 1995 31(4):210 5 7659204
Martinovic Z, Jovic N Seizure recurrence after a first generalized tonic-clonic seizure, in children, adolescents and young adults Seizure 1997 6(6):461 5 9530942
Mattson RH, Cramer JA, Collins JF A comparison of valproate with carbamazepine for the treatment of complex partial seizres and secondarily eneralized tonic-clonic seizures in adults N Engl J Med 1992 327(11):765 71 1298221
McNelis A, Musick B, Austin J, et al Psychosocial care needs of children with new-onset seizures J Neurosci Nurs 1998 30(3):161 5 9689607
Mervaala E, Keranen T, Tiihonen P, et al The effects of carbamazepine and sodium valproate on SEPs and BAEPs Electroencephalogr Clin Neurophysiol 1987 68(6):475 8 2444427
Mohan KK, Markand ON, Salanova V Diagnostic utility of video EEG monitoring in paroxysmal events Acta Neurol Scand 1996 94(5):320 5 8947283
Mulrow C, Cook DJ, Davidoff F Systematic reviews: Critical links in the great chain of evidence Ann Intern Med 1997 126(5):389 91 9054284
Mulrow CD, Oxman AD editors. Cochrane Collaboration Handbook (updated December 9, 1996). The Cochrane Collaboration. 1997;1.
Murray CJ, Lopez AD. Global Health Statistics: A compendium of incidence, prevalence, and mortality estimates for over 200 conditions. World Health Organization. 1996:610-1.
Musicco M. Randomized clinical trial on the efficacy of antiepileptic drugs in reducing the risk of relapse after a first unprovoked tonic-clonic seizure. Neurology. 1993;43:478-83. [pmid: 8450987].
Musicco M, Beghi E, Solari A, et al Treatment of first tonic-clonic seizure does not improve the prognosis of epilepsy. First Seizure Trial Group Neurology 1997 49(4):991 8 9339678
Neufeld MY, Treves TA, Chistik V, et al Sequential serum creatine kinase determination differentiates vaso-vagal syncope from generalized tonic-clonic seizures Acta Neurol Scand 1997 95(3):137 9 9088380
O'Dougherty M, Wright FS, Cox S, et al Carbamazepine plasma concentration. Relationship to cognitive impairment Arch Neurol 1987 44(8):863 7 3632397
Oka E, Yamatogi Y, Ohtsuka Y, et al Clinical course and prognosis of childhood epilepsy Acta Paediatr Jpn 1989 31(3):259 66 2508421
Olafson E, Hauser WA Prevalence of epilepsy in rural Iceland: A population-based study Epilepsia 1999 40(11):1529 34 10565579
Oldani A, Zucconi M, Smirne S, et al The neurophysiological evaluation of nocturnal frontal lobe epilepsy Seizure 1998 7(4):317 20 9733408
Oller-Daurella L, Oller LF Influence of the "lost time" on the outcome of epilepsy Eur Neurol 1991 31(3):175 7 2044634
Onsurbe Ramirez I, Hernandez Rodriguez M, Aparicio Meix JM, et al Incidence of epilepsy and epileptic syndromes in children in the province of Albacete An Esp Pediatr 1999 51(2):154 8 10495502
Panayiotopoulos CP, Chroni E, Daskalopoulos C, et al Typical absence seizures in adults: Clinical, EEG, video-EEGfindings and diagnostic/syndromic considerations J Neurol Neurosurg Psychiatry 1992 55(11):1002 8 1469393
Panayiotopoulos CP, Tahan R, Obeid T Juvenile myoclonic epilepsy: Factors of error involved in the diagnosis and treatment Epilepsia 1991 32(5):672 676 1915175
Pedersen SB, Petersen KA Juvenile myoclonic epilepsy: Clinical and EEG features Acta Neurol Scand 1998 97(3):160 3 9531431
Penry JK, Dean JC, Riela AR Juvenile myoclonic epilepsy: Long-term response to therapy Epilepsia 1989 30(Suppl 4):S19 S23
Prevey ML, Delaney RC, Cramer JA, et al Complex partial and secondarily generalized seizure patients: Cognitive functioning prior to treatment with antiepileptic medication. VA Epilepsy Cooperative Study 264 Group Epilepsy Res 1998 30(1):1 9 9551840
Prevey ML, Delaney RC, Cramer JA, et al Effect of valproate on cognitive functioning Arch Neurol 1996 53(10):1008 16 8859063
Pulliainen V, Jokelainen M Comparing the cognitive effects of phenytoin and carbamazepine in long-term monotherapy: A two-year follow-up Epilepsia 1995 36(12):1195 202 7489696
Pulliainen V, Jokelainen M Effects of phenytoin and carbamazepine on cognitive functions in newly diagnosed epileptic patients Acta Neurol Scand 1994 89(2):81 6 8191881
Reutens DC, Berkovic SF Idiopathic generalized epilepsy of adolescence: Are the syndromes clinically distinct? Neurology 1995 45(8):1469 76 7644043
Richens A, Davidson DL, Cartlidge NE, Easter DJ A multicenter comparative trial of sodium valproate and carbamazepine in adult onset epilepsy. Adult EPITEG Collaborative Group J Neurol Neurosurg Psychiatry 1994 57(6):682 7 8006647
Ring HA, Heller AJ, Marshall WJ, et al Plasma uric acid in patients receiving anticonvulsant monotherapy Epilepsy Res 1991 8(3):241 4 1868823
Roberts R, Fitch P Monitoring at the National Hospital, Queen Square, London Electroencephalogr Clin Neurophysiol 1985 37(Suppl):423 36
Sacks HS, Berrier J, Reitman D, et al. Meta-analysis of randomized controlled trials. N Engl J Med. 1987;316:450-5. [pmid: 3807986].
Sander JW, Hart YM, Johnson AL, et al National General Practice Study of Epilepsy: Newly diagnosed epileptic seizures in a general population Lancet 1990 336(8726):1267 71 1978113
Sannita WG, Gervasio L, Zagnoni P Quantitative EEG effects and plasma concentration of sodium valproate: Acute and long-term administration to epileptic patients Neuropsychobiology 1989 22(4):231 5 2518602
Saukkonen A, Kalviainen R, Partanen K, et al Do seizures cause neuronal damage? A MRI study in newly diagnosed and chronic epilepsy Neuroreport 1994 6(1):219 23 7703420
Sawhney IM, Singh A, Kaur P, et al A case control study and one year of follow-up of registered epilepsy cases in a resettlement colony of North India, a developing tropical country J Neurol Sci 1999 165(1):31 5 10426144
Sharpe C, Buchanan N Juvenile myoclonic epilepsy: Diagnosis, management and outcome Med J Aust 1995 162(3):133 4 7854224
Shihabuddin B, Abou-Khalil B, Fakhoury T The value of combined ambulatory cassette-eeg and video monitoring in the differential diagnosis of intractable seizures Clin Neurophysiol 1999 110(8):1452 7 10454281
Shinnar S, Berg AT, Moshe SL, et al The risk of seizure recurrence after a first unprovoked afebrile seizure in childhood: An extended follow-up Pediatrics 1996 98(2):216 25 8692621
Shinnar S, Berg AT, Moshe SL, et al Risk of seizure recurrence following a first unprovoked seizure in childhood: A prospective study Pediatrics 1990 85(6):1076 85 2339031
Shinnar S, Kang H, Berg AT, et al EEG abnormalities in children with a first unprovoked seizure Epilepsia 1994 35(3):471 6 8026390
Shore C, Austin J, Musick B, et al Psychosocial care needs of parents of children with new-onset seizures J Neurosci Nurs 1998 30(3):169 74 9689608
Smith DB, Mattson RH, Cramer JA, et al Results of a nationwide Veterans Administration Cooperative Study comparing the efficacy and toxicity of carbamazepine, phenobarbital, phenytoin, and primidone Epilepsia 1987 28Suppl 3:S50 S58 3319543
Sperling MR, Engel JJ Electroencephalographic recording from the temporal lobes: A comparison of ear, anterior temporal, and nasopharyngeal electrodes Ann Neurol 1985 17(5):510 3 4004174
Stefan H, Plouin P, Fichsel H, et al Progabide for previously untreated absence epilepsy Epilepsy Res 1988 2(2):132 6 3143558
Steiner TJ, Dellaportas CL, Findley LJ, et al Lamotrigine monotherapy in newly diagnosed untreated epilepsy: A double-blind comparison with phenytoin Epilepsia 1999 40(5):601 7 10386529
Tanganelli P, Regesta G Vigabatrin vs. carbamazepine monotherapy in newly diagnosed focal epilepsy: A randomized response conditional cross-over study Epilepsy Res 1996 25(3):257 62 8956924
Trudeau V, Myers S, LaMoreaux L, et al Gabapentin in naive childhood absence epilepsy: Results from two double-blind, placebo-controlled, multicenter studies J Child Neurol 1996 11(6):470 5 9120226
Turnbull DM, Howel D, Rawlins MD, et al Which drug for the adult epileptic patient: Phenytoin or valproate? BMJ 1985 290(6471):815 9 3919805 1418605
van Donselaar CA, Geerts AT, Schimsheimer RJ Idiopathic first seizure in adult life: Who should be treated? BMJ 1991 302(6777):620 3 2012874 1675477
Van Paesschen W, Duncan JS, Connelly A A comparison of the neuropathological effects of vigabatrin and carbamazepine in patients with newly diagnosed localization-related epilepsy using MR-based cerebral T2 relaxation time measurements Epilepsy Res 1998 29(2):155 60 9477148
Van Paesschen W, Duncan JS, Stevens JM, et al Longitudinal quantitative hippocampal magnetic resonance imaging study of adults with newly diagnosed partial seizures: One-year follow-up results Epilepsia 1998 39(6):633 9 9637606
Van Paesschen W, Duncan JS, Stevens JM, et al Etiology and early prognosis of newly diagnosed partial seizures in adults: A quantitative hippocampal MRI study Neurology 1997 49(-):753 7 9305336
Verity CM, Hosking G, Easter DJ A multicenter comparative trial of sodium valproate and carbamazepine in paediatric epilepsy. The Paediatric EPITEG Collaborative Group Dev Med Child Neurol 1995 37(2):97 108 7851677
Walsh JC, Vignaendra V, Burrows S, et al The application of prolonged electroencephalographic monitoring and video recording to the diagnosis of epilepsy Med J Aust 1986 144(8):401 4 3083218
Wiebe S, Bellhouse DR, Fallahay C, et al Burden of epilepsy: The Ontario Health Survey Can J Neurol Sci 1999 26(4):263 70 10563210
Williams J, Bates S, Griebel ML, et al Does short-term antiepileptic drug treatment in children result in cognitive or behavioral changes? Epilepsia 1998 39(10):1064 9 9776326
Wolf P Non-medical treatment of first epileptic seizures in adolescence and adulthood Seizure 1995 4(2):87 94 7670772
Zamponi N, Cardinali C Open comparative long-term study of vigabatrin vs. carbamazepine in newly diagnosed partial seizures in children Arch Neurol 1999 56(5):605 7 10328256