# References

Aikia M, Kalviainen R, Mervaala E, et al Predictors of seizure outcome in newly diagnosed partial epilepsy: Memory performance as a prognostic factor Epilepsy Res 1999 37(2):159 67 10510982
Aikia M, Kalviainen R, Sivenius J, et al Cognitive effects of oxcarbazepine and phenytoin monotherapy in newly diagnosed epilepsy: One year follow-up Epilepsy Res 1992 11(3):199 203 1396535
Ambrosetto G, Giovanardi RP, Tassinari CA Predictive factors of seizure frequency and duration of antiepileptic treatment in rolandic epilepsy: A retrospective study Brain Dev 1987 9(3):300 4 3661910
Anzola GP Predictivity of plasma prolactin levels in differentiating epilepsy from pseudoseizures: A prospective study Epilepsia 1993 34(6):1044 48 8243355
Arts WF, Geerts AT, Brouwer OF, et al The early prognosis of epilepsy in childhood: The prediction of a poor outcome. The Dutch study of epilepsy in childhood Epilepsia 1999 40(6):726 34 10368070
Atakli D, Sozuer D, Atay T, et al Misdiagnosis and treatment in juvenile myoclonic epilepsy Seizure 1998 7(1):63 6 9548228
Baker GA, Nashef L, van Hout BA Current issues in the management of epilepsy: The impact of frequent seizures on cost of illness, quality of life, and mortality Epilepsia 1997 38(Suppl)1:1 8
Beghi E, Tognoni G Prognosis of epilepsy in newly referred patients: A multicenter prospective study Collaborative Group for the Study of Epilepsy Epilepsia 1988 29(3):236 43
Begley CE, Famulari M, Annegers JF, et al The cost of epilepsy in the United States: An estimate from population-based clinical and survey data Epilepsia 2000 41(3):342 51 10714408
Beilmann A, Napa A, Soot A, et al Prevalence of childhood epilepsy in Estonia Epilepsia 1999 40(7):1011 9 10403228
Berg AT, Shinnar S, Levy SR, et al Newly diagnosed epilepsy in children: Presentation at diagnosis Epilepsia 1999a 40(4):445 52 10219270
Berg AT, Shinnar S, Levy SR, et al Status epilepticus in children with newly diagnosed epilepsy Ann Neurol 1999b 45(5):618 23 10319884
Bora I, Seckin B, Zarifoglu M, et al Risk of recurrence after first unprovoked tonic-clonic seizure in adults J Neurol 1995 242(3):157 63 7751859
Braathen G, Theorell K A general hospital population of childhood epilepsy Acta Paediatrica 1995 84(10):1143 6 8563226
Bye A, Lamont P, Healy L. Commencement of a pediatric EEG-video telemetry service. Clin Exp Neurol. 1990;27:83-8. [pmid: 2129962].
Callaghan N, Kenny RA, O'Neill B, et al. A prospective study between carbamazepine, phenytoin and sodium valproate as monotherapy in previously untreated and recently diagnosed patients with epilepsy. J Neurol Neurosurg Psychiatry. 1985;48:639-44. [pmid: 3928820].
Camfield PR, Camfield CS, Dooley JM, et al Epilepsy after a first unprovoked seizure in childhood Neurology 1985a 35(11):1657 60 4058756
Camfield PR, Camfield CS, Smith EC, et al Newly treated childhood epilepsy: A prospective study of recurrences and side effects Neurology 1985b 35(5):722 725 3990971
Caplan LR, editor. Should single epileptic seizures be treated?. Eur Neurol. 1994;34:186-92. [pmid: 8082676].
Carenini L, Bottacchi E, Camerlingo M, et al Carbamazepine does not affect short-latency somatosensory evoked potentials: A longitudinal study in newly diagnosed epilepsy Epilepsia 1988 29(2):145 8 3349965
Carpay JA, de Weerd AW, Schimsheimer RJ, et al The diagnostic yield of a second EEG after partial sleep deprivation: A prospective study in children with newly diagnosed seizures Epilepsia 1997 38(5):595 9 9184606
Casetta I, Granieri E, Monetti VC, et al Early predictors of intractability in childhood epilepsy: A community-based case-control study in Copparo, Italy Acta Neurol 1999 99(6):329 33
Chen LS, Mitchell WG, Horton EJ, et al Clinical utility of video-EEG monitoring Pediatr Neurol 1995 12(3):220 224 7619188
Chu NS Long-term ambulatory cassette EEG with sphenoidal recording in complex partial seizures Epilepsia 1991 32(3):351 7 2044498
Cockerell OC, Johnson AL, Sander JW, et al Prognosis of epilepsy: A review and further analysis of the first nine years of the British National General Practice Study of Epilepsy, a prospective population-based study Epilepsia 1997 38(1):31 46 9024182
Cook DJ, Guyatt GH, Laupacis A, et al. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest. 1992;102:305-11.
Cull RE An assessment of 24-hour ambulatory EEG/ECG monitoring in a neurology clinic J Neurol Neurosurg Psychiatry 1985 48(2):107 10 3981167
Dam AM, Fuglsang-Frederiksen A, Svarre-Olsen U, et al Late-onset epilepsy: Etiologies, types of seizure, and value of clinical investigation, EEG, and computerized tomography scan Epilepsia 1985 26(3):227 31 4006882
Devinsky O, Vickrey BG, Cramer J, et al Development of the quality of life in epilepsy inventory Epilepsia 1995 36(11):1089 104 7588453
Drake MEJ, Weate SJ, Newell SA, et al Multiple sleep latency tests in epilepsy Clin Electroencephalogr 1994 25(2):59 62 8194189
Duchowny MS, Resnick TJ, Deray MJ, et al Video EEG diagnosis of repetitive behavior in early childhood and its relationship to seizures Pediatr Neurol 1988 4(3):162 4 3149479
Ferrarese C, Tortorella R, Bogliun G, et al Decreased density of lymphocyte benzodiazepine receptors in drug-resistant epileptic patients Epilepsy Res 1997 27(3):181 5 9237052
Foley CM, Legido A, Miles DK, et al Diagnostic value of pediatric outpatient video-EEG Pediatr Neurol 1995 12(2):120 4 7779208
Forsgren L Prospective incidence study and clinical characterization of seizures in newly referred adults Epilepsia 1990 31(3):292 301 2344846
Forsgren L, Bucht G, Eriksson S, et al Incidence and clinical characterization of unprovoked seizures in adults: A prospective population-based study Epilepsia 1996 37(3):224 9 8598179
Forsythe I, Butler R, Berg I, et al Cognitive impairment in new cases of epilepsy randomly assigned to carbamazepine, phenytoin and sodium valproate Dev Med Child Neurol 1991 33(6):524 34 1864478
Frost JDJ, Hrachovy RA, Glaze DG, et al Alpha rhythm slowing during initiation of carbamazepine therapy: implications for future cognitive performance J Clin Neurophysiol 1995 12(1):57 63 7896910
Grabow JD Complementary roles of EEG and CT Postgrad Med 1985 77(4):207 22 3919377
Grunewald RA, Chroni E, Panayiotopoulos CP Delayed diagnosis of juvenile myoclonic epilepsy J Neurol Neurosurg Psychiatry 1992 55(6):497 9 1619419
Gunduz E, Demirbilek V, Korkmaz B Benign rolandic epilepsy findings Seizure 1999 8(4):246 9 10452925
Harvey AS, Berkovic SF, Wrennall JA, et al Temporal lobe epilepsy in childhood: Clinical, EEG, and neuroimaging findings and syndrome classification in a cohort with new-onset seizures Neurology 1997 49(4):960 8 9339674
Hauser WA, Rich SS, Annegers JF, et al. Seizure recurrence after a first unprovoked seizure: An extended follow-up. Neurology. 1990;40:1163-70. [pmid: 2381523].
Hauser WA, Rich SS, Lee JR, et al Risk of recurrent seizures after two unprovoked seizures N Engl J Med 1998 338(7):429 34 9459646
Living well with epilepsy: Report of the 1997 National Conference on Public Health and Epilepsy. CDC and NCCDPHP. 1998.
Henneman PL, DeRoos F, Lewis RJ Determining the need for admission in patients with new-onset seizures Ann Emerg Med 1994 24(6):1108 14 7978592
Hoefnagels WA, Padberg GW, Overweg J, et al Transient loss of consciousness: The value of the history for distinguishing seizure from syncope J Neurol 1991 238(1):39 43 2030371
Holt-Seitz A, Wirrell EC, Sundaram MB Seizures in the elderly: Etiology and prognosis Can J Neuro Sci 1999 26(2):110 4
Hopkins A, Garmon A, Clarke C The first seizure in adult life Lancet 1988 1(8588):721 6 2895259
Hughes JR, Gruener G The success of EEG in confirming epilepsy -- Revisited Clin Electroencephalogr 1985 16(2):98 103 4006231
Isojarvi JI, Pakarinen AJ, Myllyla VV. Serum lipid levels during carbamazepine medication. Arch Neurol. 1993;50:590-3. [pmid: 8099275].
Jadad AR, Moore A, Carroll D, et al. Assessing the quality of reports of randomized controlled trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jallon P, Goumaz M, Haenggeli C, et al Incidence of first epileptic seizures in the canton of Geneva, Switzerland Epilepsia 1997 38(5):547 52 9184600
Kalviainen R, Aikia M, Helkala EL, et al Memory and attention in newly diagnosed epileptic seizure disorder Seizure 1992 1(4):255 62 1344774
Kalviainen R, Aikia M, Saukkonen AM, et al Vigabatrin vs. carbamazepine monotherapy in patients with newly diagnosed epilepsy. A randomized, controlled study Arch Neurol 1995 52(10):989 96 7575227
Kilpatrick CJ, Tress BM, O'Donnell C, et al Magnetic resonance imaging and late-onset epilepsy Epilepsia 1991 32(3):358 64 1904345
King MA, Newton MR, Jackson GD, et al Epileptology of the first-seizure presentation: A clinical, electroencephalographic, and magnetic resonance imaging study of 300 consecutive patients Lancet 1998 352(9133):1007 11 9759742
Kline Leidy N, Rentz AM, Grace EM Evaluating health-related quality of life outcomes in clinical trials of antiepileptic drug therapy Epilepsia 1998 39(9):965 77 9738676
Konishi T, Naganuma Y, Hongou K, et al Effects of antiepileptic drugs on EEG background activity in children with epilepsy: Initial phase of therapy Clin Electroencephalogr 1995 26(2):113 9 7781190
Kun LN, Ling LW, Wah YW, et al Epidemiologic study of epilepsy in young Singaporean men Epilepsia 1999 40(10):1384 7 10528933
Larkin JG, McKee PJ, Brodie MJ Rapid tolerance to acute psychomotor impairment with carbamazepine in epileptic patients Br J Clin Pharmacol 1992 33(1):111 4 1540481
Lee SI Nonconvulsive status epilepticus. Ictal confusion in later life Arch Neurol 1985 42(8):778 81 4026612
Luhdorf K, Jensen LK, Plesner AM Epilepsy in the elderly: Prognosis Acta Neurol Scand 1986 74(5):409 15 3825499
Mandelbaum DE, Burack GD The effect of seizure type and medication on cognitive and behavioral functioning in children with idiopathic epilepsy Dev Med Child Neurol 1997 39(11):731 5 9393886
Marciani MG, Maschio MC, Spanedda F, et al Sodium valproate and mental processes in newly referred epileptic patients. A computerized EEG study Neuropsychobiology 1995 31(4):210 5 7659204
Martinovic Z, Jovic N Seizure recurrence after a first generalized tonic-clonic seizure, in children, adolescents and young adults Seizure 1997 6(6):461 5 9530942
McNelis A, Musick B, Austin J, et al Psychosocial care needs of children with new-onset seizures J Neurosci Nurs 1998 30(3):161 5 9689607
Mohan KK, Markand ON, Salanova V Diagnostic utility of video EEG monitoring in paroxysmal events Acta Neurol Scand 1996 94(5):320 5 8947283
Mulrow C, Cook DJ, Davidoff F Systematic reviews: Critical links in the great chain of evidence Ann Intern Med 1997 126(5):376 80 9054282
Mulrow CD, Oxman AD, editors. Cochrane Collaboration Handbook (updated December 9, 1996). The Cochrane Collaboration. 1997;1.
Murray CJ, Lopez AD. Global Health Statistics: A compendium of incidence, prevalence, and mortality estimates for over 200 conditions. World Health Organization. 1996:610-11.
Neufeld MY, Treves TA, Chistik V, et al Sequential serum creatine kinase determination differentiates vaso-vagal syncope from generalized tonic-clonic seizures Acta Neurol Scand 1997 95(3):137 9 9088380
O'Dougherty M, Wright FS, Cox S, et al Carbamazepine plasma concentration. Relationship to cognitive impairment Arch Neurol 1987 44(8):863 7 3632397
Olafson E, Hauser WA Prevalence of epilepsy in rural Iceland: A population-based study Epilepsia 1999 40(11):1529 34 10565579
Oldani A, Zucconi M, Smirne S, et al The neurophysiological evaluation of nocturnal frontal lobe epilepsy Seizure 1998 7(4):317 20 9733408
Oller-Daurella L, Oller LF Influence of the "lost time" on the outcome of epilepsy Eur Neurol 1991 31(3):175 7 2044634
Onsurbe Ramirez I, Hernandez Rodriguez M, Aparicio Meix JM, et al Incidence of epilepsy and epileptic syndromes in children in the province of Albacete An Esp Pediatr 1999 51(2):154 8 10495502
Panayiotopoulos CP, Tahan R, Obeid T Juvenile myoclonic epilepsy: Factors of error involved in the diagnosis and treatment Epilepsia 1991 32(5):672 6 1915175
Panayiotopoulos CP, Chroni E, Daskalopoulos C, et al Typical absence seizures in adults: Clinical, EEG, video-EEG findings and diagnostic/syndromic considerations J Neurol Neurosurg Psychiatry 1992 55(11):1002 8 1469393
Penry JK, Dean JC, Riela AR Juvenile myoclonic epilepsy: Long-term response to therapy Epilepsia 1989 30(Suppl 4):S19 23
Pulliainen V, Jokelainen M Effects of phenytoin and carbamazepine on cognitive functions in newly diagnosed epileptic patients Acta Neurol Scand 1994 89(2):81 6 8191881
Reutens DC, Berkovic SF Idiopathic generalized epilepsy of adolescence: Are the syndromes clinically distinct? Neurology 1995 45(8):1469 76 7644043
Roberts R, Fitch P Monitoring at the National Hospital, Queen Square, London Electroencephalogr Clin Neurophysiol 1985 37(Suppl):423 36
Sacks HS, Berrier J, Reitman D, et al. Meta-analysis of randomized controlled trials. N Engl J Med. 1987;316:450-5. [pmid: 3807986].
Sander JW, Hart YM, Johnson AL, et al National General Practice Study of Epilepsy: Newly diagnosed epileptic seizures in a general population Lancet 1990 336(8726):1267 1271 1978113
Sannita WG, Gervasio L, Zagnoni P Quantitative EEG effects and plasma concentration of sodium valproate: Acute and long-term administration to epileptic patients Neuropsychobiology 1989 22(4):231 5 2518602
Sawhney IM, Singh A, Kaur P, et al A case control study and one year of follow-up of registered epilepsy cases in a resettlement colony of North India, a developing tropical country J Neurol Sci 1999 165(1):31 5 10426144
Sharpe C, Buchanan N Juvenile myoclonic epilepsy: Diagnosis, management and outcome Med J Aust 1995 162(3):133 4 7854224
Shihabuddin B, Abou-Khalil B, Fakhoury T The value of combined ambulatory cassette-EEG and video monitoring in the differential diagnosis of intractable seizures Clin Neurophysiol 1999 110(8):1452 7 10454281
Shinnar S, Berg AT, Moshe SL, et al The risk of seizure recurrence after a first unprovoked afebrile seizure in childhood: An extended follow-up Pediatrics 1996 98(2):216 25 8692621
Smith DB, Mattson RH, Cramer JA, et al Results of a nationwide Veterans Administration Cooperative Study comparing the efficacy and toxicity of carbamazepine, phenobarbital, phenytoin, and primidone Epilepsia 1987 28(Suppl 3):S50 S58 3319543
Sperling MR, Engel JJ Electroencephalographic recording from the temporal lobes: A comparison of ear, anterior temporal, and nasopharyngeal electrodes Ann Neurol 1985 17(5):510 3 4004174
Stefan H, Plouin P, Fichsel H, et al Progabide for previously untreated absence epilepsy Epilepsy Res 1988 2(2):132 6 3143558
Steiner TJ, Dellaportas CL, Findley LJ, et al Lamotrigine monotherapy in newly diagnosed untreated epilepsy: A double-blind comparison with phenytoin Epilepsia 1999 40(5):601 7 10386529
Van Paesschen W, Duncan JS, Stevens JM, et al. Etiology and early prognosis of newly diagnosed partial seizures in adults: A quantitative hippocampal MRI study. Neurology. 1997;49:753-7. [pmid: 9305336].
Wiebe S, Bellhouse DR, Fallahay C, et al Burden of epilepsy: The Ontario Health Survey Can J Neurol Sci 1999 26(4):263 70 10563210
Williams J, Bates S, Griebel ML, et al Does short-term antiepileptic drug treatment in children result in cognitive or behavioral changes? Epilepsia 1998 39(10):1064 9 9776326