# Acknowledgments

The authors wish to acknowledge the following individuals for their diverse contributions throughout the course of this task order: Rebecca Cintron, Janet Connelly, Matthew Gordon, Cindy Levine, Joanne Levy, Elaine Milardo, Luba Nalysnyk, Michael Rozinsky, Shuhuan Zhang, and Isabella Sledge.