# Future Research in Newly Diagnosed Patients

It is clear from this review of the literature addressing newly diagnosed patients that more research is needed to answer basic questions of diagnosis, monitoring, and treatment. This new research can be categorized as better studies and more studies. In the better studies category, we suggest the following:

1. All future diagnostic studies should measure and report sensitivity and specificity. This will require that a gold standard for diagnosis be agreed on. At this time, it seems this gold standard should be a clinical/EEG standard according to the latest ILAE classification scheme.
2. Treatment trials should use common terminology, e.g., distinguishing seizures from epilepsy and defining "newly diagnosed" in a common way, enrolling "pure" populations of patients with unprovoked seizures, and using common definitions of "optimum" outcomes inclusive of both seizures and side effects domains.
3. Treatment trials should use a core set of efficacy outcomes that are comparable across trials, e.g. seizure remission rates, time to recurrence, mean number of seizures per patient per unit of time, and time to remission.
4. Treatment trials need to report more often the efficacy, safety, and compliance associated with AEDs, in the long term.
5. All new trials should include "patient-centered" outcomes whenever appropriate, e.g., QoL, health care utilization measures, and the economic impact of interventions. Different research methods may be required to optimally study these outcomes.

In the more studies category, we suggest:

1. Studies relating the volume of practice (as a hypothesized surrogate for clinical/pharmacologic expertise) to patient outcomes. These would include studies of the consequences of delayed diagnosis or misdiagnosis on outcomes.
2. Studies of the individual components of clinical/pharmacologic expertise to determine which of these components may or may not affect patient outcomes and which are related to volume of practice.
3. Studies based outside of academic/epilepsy centers (e.g., community-based studies) that would better capture populations with new onset epilepsy and would include other caregivers besides academic neurologists.
4. Studies of the impact of patient counseling, education, and support interventions on patient outcomes.
5. Studies of the impact of both old and newer (e.g., Internet based) patient monitoring methods on patient outcomes.

Journal editors and reviewers should solicit and give preference to such studies, as well as raise the standard for the type of material acceptable for publication. More commentaries, opinions, narrative reviews, and anecdotes are not going to advance the field.