# Conclusions

The current literature can only partially assist in answering questions as to the appropriate and necessary health care interventions pertinent to the diagnosis, monitoring, and treatment of patients with newly diagnosed epilepsy. The evidence base can be efficiently updated as the literature evolves and/or expanded to include other patient populations and/or data elements not captured in the original scope of work. Although the development of practice guidelines or specific clinical recommendations was beyond the scope of this project, this evidence base may be a useful starting point for health care providers in the development of strategies and algorithms to guide the management of patients with a first diagnosis of epilepsy. Knowing what we do and do not know is of value. This work should provide guidance for researchers to generate new and better data to fill the information gaps discovered during the review.