# Results

## Search Results

The initial searches of MEDLINE and Current Contents spanned from 1980 to April 15, 1999, and yielded a total of 12,227 citations. Following Phase II, Part A, of this project, a total of 401 citations were accepted during Level I screening and classified as addressing the population "Patients Undergoing First Diagnosis." The full-text publications of these citations were retrieved for Level II screening.

Employing identical search criteria, we updated the MEDLINE search through December 1, 1999, downloading 675 additional abstracts for Level I screening. MetaWorks also updated the Current Contents search from November 16, 1998, to November 8, 1999, employing the search terms "epilepsy" and "diagnosis." This search yielded 514 abstracts. After eliminating duplicate studies between MEDLINE and Current Contents, a total of 901 new abstracts were downloaded for Level I screening.

To supplement the yield from these searches, we identified pertinent reviews, systematic reviews, and meta-analyses whose bibliographies were subsequently examined for additional publications. In a search of the Cochrane Library of Systematic Reviews, MetaWorks identified 4 full systematic reviews and 31 abstracts of systematic reviews that addressed topics within the scope of this project. From a MEDLINE search of review articles spanning from 1996 to 1999, MetaWorks identified 115 abstracts that addressed the topic of diagnosis of epilepsy. After these abstracts were screened, it was determined that 18 review publications fell within the scope of this project and were retrieved. After the bibliographies of all review articles and accepted studies were searched, 39 additional citations were identified and retrieved for Level II screening (Figure 4). Nineteen of these studies met all criteria for inclusion and are part of the final set of accepted studies.

Figure 4. Study Attrition

In summary, a total of 13,128 abstracts underwent Level I screening over the duration of this project. Most citations were rejected at Level I for reasons of ineligible patient populations, with the remaining 462 citations retrieved for Level II screening. During Level II screening, 303 studies (k) were excluded for the following reasons: no population of interest (k=208); reviews, meta-analyses, letters, case reports, editorials, and commentaries (k=52); outcomes not extractable (k=18); fewer than 10 patients total sample size (k=10); results for population of interest not separable from results of other populations (k=9); pharmacokinetic/ pharmacodynamic study (k=2); foreign language (k=1); no outcomes of interest (k=1); no outcomes reported (k=1); and major data inconsistencies in report (k=1). These figures include 15 studies that were rejected during data extraction for a variety of the reasons above. All studies rejected during Level II screening or data extraction are listed in the study reject log.

The final set of accepted studies includes 120 primary ("parent") studies and 33 linked ("kinship") studies. All accepted parent and kinship studies are listed in the accepted study log.

## Study Characteristics

Study characteristics are summarized in Evidence Tables 1 and 2. There were 70 interventional studies (31 RCTs) and 50 observational trials (33 retrospective and 17 prospective). All studies were in English. Thirty-one studies were performed in North America, 74 in Europe, and 18 elsewhere, including Australia, Israel, and Japan. The sum of the location categories is greater than the total because three interventional studies were conducted in both North America and Europe. The years of publication spanned 1980 through 1999, with most studies published since 1990. Maximum study durations overall averaged 19.1 months for interventional studies and 81.4 months for observational studies. The maximum study durations in the observational prospective designs were shorter on average than in the retrospective studies (62.4 months and 101.9 months, respectively). The mean or median duration ranged from 3 days to 10 years.

The mean score on the composite evidence rating instrument was 1.2 (0.3 to 5.0) for the interventional trials and 0.3 for the observational studies. A formal classification system for epilepsy syndrome or seizure type was reported in only one-half of the interventional and observational studies and in nearly all cases was the International League Against Epilepsy (ILAE) classification schema. Most studies cited the older (1981) version of the ILAE classification.

Industry sponsorship was noted in 26 studies, the majority of which were RCTs of AEDs. A cost assessment was reported in only two studies, both nRCT interventional designs. Foley, Legido, Miles, et al. (1995) reported the results of a video EEG diagnostic study on 36 patients in North America, and Oldani, Zucconi, Smirne, et al., (1998) reported the results of daytime video EEG for nocturnal frontal lobe epilepsy diagnosis on 23 patients in Europe.

A QoL result was available in only three studies, two RCTs and one retrospective. The one retrospective study did not specify the QoL instrument (Luhdorf, Jensen, and Plesner, 1986). A Veterans Administration Cooperative Group Study of four AEDs referred to the Cramer scale (Smith, Mattson, Cramer, et al., 1987). The third study was an RCT of lamotrigine and phenytoin and used the Side Effects and Life Satisfaction Scale (SEALS) (Steiner, 1999).

The level and type of clinical expertise of the clinical investigators could only be assumed from the affiliations provided, in most instances. These suggested a single area of expertise in slightly fewer than one-half of the studies, with neurologists predominating. No studies appeared to be led by primary care physicians or internists, surgeons, or radiologists. The usual provider of epilepsy care could be identified in only six studies: a neurologist in five (Berg, Shinnar, Levy, et al. 1999a,b; Casetta, Granieri, Monetti, et al., 1999; Foley, Legido, Miles, et al., 1995; Frost, Hrachovy, Grace, et al., 1995; Harvey, Berkovic, Wrennal, et al.,1997) and a primary care physician in one (Panayiotopoulos, Tahan, and Obeid, 1991).

Intervention locations were assumed to be the locations noted in the authors' affiliations unless otherwise stated. As such, academic hospitals predominated for both the interventional studies and the observational studies, with epilepsy centers, usually in association with academic centers also, a distant second. In only one study was the intervention judged to occur at home (Cull, 1985; re: 24-hour ambulatory EEG); and in 12 others, at an office or clinic setting.

The primary objective of 21 studies was to determine prognostic factors and/or recurrence risk . These studies are discussed below with regard to results. Ten studies had measurement of cognitive status of new patients as a primary objective. Although 64 reports were categorized as treatment studies in the database, no studies stated a primary objective of assessing AED compliance. The AEDs under study included carbamazepine most often (k=35), but also valproate (k=21), vigabatrin (k=7), phenobarbital (k=6), oxcarbazepine, and phenytoin in four studies each; gabapentin, lamotrigine, and ethosuximide in three studies each; and clonazepine and primidone in one study each. A total of 25 studies reported compliance, as measured by pill counts (k=3), drug levels (k=19), or other means (k=3). No studies stated a primary objective of assessing the effect of education or counseling, although one study (McNelis, Musick, Austin, et al., 1998) intended to measure psychosocial outcomes in children. Four other studies had a primary objective of measuring neuropsychiatric or psychomotor status in new patients (Forsyth, Butler, Berg, et al., 1991; Frost, Hrachovy, Glaze, et al., 1995; Gunduz, Demirbilek, and Korkmaz, 1999; Larkin, McKee, and Brodie, 1992). There were no surgery studies in this set.

## Patient Characteristics

As shown in Evidence Table 2, patients were enrolled at the time of their first seizure in 17 studies, at the time of their first presentation in 14 studies, or just after a new diagnosis in 62 studies. Studies enrolling patients at none of the above times, but with the time of first diagnosis (time zero) clearly in the window of observation, totaled 26. Most of these "time zero" studies (23 of 26) were retrospective in design. In one study, this information was not discernable (Penry, Dean, and Reila, 1989). Specific inclusion criteria for newly diagnosed patients with regard to the number of seizures in a designated interval were noted in 59 studies and varied highly, from one seizure in the past week, to >2 seizures in the past 2 to 36 months, to >3 seizures in the past 6 months. A requirement that seizures be unprovoked was noted in 33 studies. In the remainder, the presence of provoking factors was either permitted (with or without specification as to which) or not reported. Explicit exclusions for secondary causes of seizures were noted in 64 studies, and typically these were conditions known to be associated with seizures, e.g., brain tumor, trauma, stroke, infection, or progressive neurologic disease. In the majority of studies, the presence of specific signs or symptoms at study entry was not reported, and therefore the relationship of specific signs and symptoms to outcomes of interventions cannot be directly assessed here.

Evidence Table 3 displays patient characteristics. The total number of patients enrolled in these studies was 21,213. There were 38 studies restricted to pediatric populations and 38 restricted to adults, and the remainder enrolled both (k=44). Of the 120 accepted studies, gender was reported in 95, of which a slight majority of patients were male. Race was only reported in nine studies, and of these, nearly one-half were Caucasian. The remainder were variably distributed among African American, Hispanic, and Asian groups. Of 35 observational studies that reported age, the average age was 23 years (range 0 to 90 years). Of the 63 interventional trials reporting age, the average was 28.5 years (range 0 to 91 years). Family history was noted in only 20 studies and was positive in a minority of patients. In 54 studies, prior use of AEDs was noted in only 8 to 10 percent of patients. AED use at entry was noted in 68 studies, in which 2.1 percent (interventional) to 19.1 percent (observational) of patients reported such use. The type of seizure or epilepsy diagnosis at study entry was reported in 52 interventional studies and 39 observational studies. In the former, the distribution between patients with generalized and partial seizures is about even, but in the latter, far more patients were reported to have generalized tonic clonic seizures than other types. There is little information in these studies about how carefully seizures were classified with regard to onset patterns versus ending patterns; such information is relevant, since many generalized seizures in adults are in fact focal in onset. The percentages shown in Evidence Table 3 do not sum to 100 percent because of incomplete reporting of all seizure types in all studies contributing data.

## Interventions

The following sections are organized to first describe results by category and type of intervention and, second, to synthesize these results in order to answer the specific project questions posed in Chapter 1, Introduction. Where study populations are known to be entirely children or entirely adult, this is so stated. Otherwise study populations are referred to generally as "patients."

### Diagnosis

There were five observational studies, all in Europe, reporting incidence of new diagnoses (Braathen and Theorell, 1990; Forsgren, 1990; Forsgren, Bucht, Eriksson, et al. 1996; Jallon, Goumaz, Haenggeli, et al., 1997, Luhdorf, Jensen, and Plesner, 1986). The incidence results ranged from 0.03 percent to 0.08 percent in patients with all seizure types and all ages represented. These figures are similar to the incidence estimates for established market economies noted above (see Background section in Chapter 1).

Evidence Tables 4, 4a, 5, and 5a summarize selected results from studies with diagnostic information. Several studies of diagnostic interventions described what could be loosely construed as a "gold standard" for the diagnosis of epilepsy. These gold standards tended to include both a clinical component and an EEG component. The clinical requirements for diagnosis were highly variable, however, and included such signs and symptoms as tonic/clonic movements, with or without post-ictal confusion, tongue biting, sphincter disturbance, aura, and loss of consciousness. Some studies required the events to be unprovoked; others did not. Some studies required the events be witnessed; others did not. The seizure type was usually diagnosed by clinical features and the epilepsy syndrome, by seizure type and EEG findings. Only a minority referred to established classification schemas, e.g., ILAE or WHO.

There were 12 prospective interventional trials reporting results of a diagnostic intervention: 6 were in patients at the time of first diagnosis, 4 at the time of first presentation, and 2 at the time of first seizure. There were 26 observational studies, which included "time zero" for diagnosis in the observation window. Most of the studies reporting the use of diagnostic interventions did not provide the numbers of patients with a new or changed diagnosis as a result of the intervention. Rather, these studies typically reported the use of the intervention as discretionary by the study investigators or as occurring in some patients at the time of study entry, but no further details are provided.

The role of history and physical examination was touched on in several studies. Berg, Shinnar, Levy, et al., (1999a, 1999b) reported that 609 of 613 children were assigned a syndromic diagnosis on the basis of clinical features. Arts, Geerts, Brouwer, et al., (1999) reporting on 466 children suggested the history alone yielded a 29 percent sensitivity and 89 percent specificity. The study by Hoefnagels, Padblerg, Overweg, et al., (1991) noted that it is impossible to find a gold standard for the diagnosis of epilepsy and therefore developed its own to distinguish epilepsy from syncope. Sensitivity and specificity of several components of a history were computed, e.g., particular symptoms before, during, and after the paroxysmal event. Those before the event tended to the highest sensitivity (88 percent to 98 percent), and those during the event, the highest specificity (64 percent to 94 percent). Camfield, Camfield, Dooley, et al. (1985a) reported that in a retrospective analysis of 168 children seen after their first seizure, an abnormal neurologic examination (in 30 patients) was predictive of recurrence, as was seizure type (partial seizure associated with increased risk). Neither the sleep-wake status at the first seizure nor a history of febrile seizures predicted recurrence. In three additional retrospective studies, the utility of various interventions in diagnosis and/or prediction of recurrence was reported. Ambrosetto, Giovanardi, and Tassinari (1987) reported on history (and EEG findings) in 72 patients and concluded that only generalized seizures as the sole ictal phenomenon, and a long interval between the first and second seizures, were predictive of seizure frequency subsequently.

King, Newton, Jackson, et al. (1998) reported that early EEGs, within 24 hours of seizure, yielded a diagnosis in 77 percent (232/300) patients. Martinovic and Jovic (1997) related the risk of recurrence in children after a first seizure to the finding of epileptiform patterns on standard EEG. Carpay, de Weerd, Schimsheimer, et al. (1997) reported the diagnostic yield of standard EEGs and sleep-deprived EEGs after a normal standard EEG. Of 552 standard EEGs in children with first seizures, 243 were normal and 309 were epileptiform. Sleep-deprived EEGs in the normal EEG patients added 11 percent more diagnoses to the 56 percent of patients with diagnosis after abnormal standard EEGs. Hughes and Gruener (1985) reported the use of standard EEGs in confirming seizures in patients with a new diagnosis of epilepsy. The history was noncontributory, but the standard EEG was abnormal in 300 of 358 patients, supporting its use in first diagnosis. Sperling and Engel (1985) studied the utility of additional electrodes in the EEG diagnosis of 98 patients who had normal standard EEGs but who were suspected of having temporal lobe epilepsy. Ear, anterior temporal, or nasopharyngeal electrodes did not increase the diagnostic yield. Chu (1991) studied the utility of sphenoidal recording during both standard and ambulatory EEGs. The increased yield was marginal.

There were several studies of video EEG in diagnosis. Oldani, Zucconi, Smirne, et al. (1998) reported that daytime video EEG was not diagnostic in any of 23 patients suspected of nocturnal frontal lobe epilepsy. After sleep deprivation, however, video EEG was diagnostic in 12 of 20, compared with nocturnal video polysomnography in 20 of 23 patients. Shihabuddin, Abou-Khalil, and Fakhoury (1999) reported on 123 patients with attacks of unknown nature, in whom standard EEG, CT, and MRI were nondiagnostic. Ambulatory EEG with video monitoring yielded a diagnosis in 81. The number of patients judged to have epilepsy was decreased as a result of this intervention, from 31 to 20 patients. Bye, Lamont, and Healy (1990) reported that 66 of 82 children had paroxysmal events documented on video EEG, 23 of which were ictal, leading to diagnosis. Foley, Legido, Miles, et al. (1995) reported that outpatient video EEG was diagnostic in 32 of 36 children with suspected epilepsy. Cull (1985) assessed the utility of 24-hour ambulatory EEG versus standard EEG. The latter was abnormal in 16 of 62 patients and the former, abnormal in 21 patients. Ambulatory EEG was not superior to standard EEG if attacks occurred at frequencies of fewer than one per week. Seven of 46 patients with normal standard EEGs were abnormal on ambulatory recordings. Conversely, 2 of 16 abnormal standard EEGs were normal during ambulatory EEGs.

Four retrospective studies also assessed video EEGs. Duchowny, Resnick, Deray, et al. (1988) studied 60 young children; a first diagnosis was made possible in 9 or the 60 and a change in diagnosis was made in 24. Mohan, Markand, and Salanova (1996) reviewed results in 444 patients with video EEG. This intervention led to a diagnosis of psychogenic seizures in 141 patients and an epilepsy diagnosis in 180 patients. In 123 patients, video EEG was not diagnostic. The authors noted that if the frequency of episodes is greater than one per week, the video EEG is more likely to yield a diagnosis. Chen, Mitchell, Horton, et al. (1995) retrospectively studied video EEG in diagnosis and treatment decisions in 138 children. A diagnosis was made possible in 96 (70 percent). Roberts and Fitch (1985) reported the diagnostic utility of video and ambulatory EEGs in 102 patients. In 57 patients, the video EEG led to a diagnosis, which was epilepsy in 19. In a further 20, the ambulatory EEG led to a diagnosis, which was epilepsy in 3.

Blood tests in diagnosis were evaluated in very few studies. Anzola (1993) found normal serum prolactin levels in patients with syncope, but elevated levels in patients with epilepsy. Positive predictive value (PPV) was 89 percent and negative predictive value (NPV), 61 percent. Neufeld, Treves, Chistik, et al. (1997) studied the use of sequential creatine kinase (CK) measurements to differentiate syncope from generalized tonic clonic seizures in adults at the time of first seizure. Admission CK was increased in 25 percent of seizure patients versus 6 percent of syncope patients. At 24 hours, CK was increased in 56 percent of seizure patients and 12 percent of syncope patients. An absolute increase in CK of 15 milliunits/ml gave a diagnostic sensitivity of 69 percent and specificity of 94 percent.

The evidence is clear that diagnostic interventions will vary in their utility according to the patient population studied. For example, there are several studies restricted to elderly patients with new epilepsy, most of which suggest an increased likelihood of abnormal EEGs and CT scans and the relative lack of utility of the history alone in diagnosis. Holt-Seitz, Wirrell, and Sundaram (1999) assessed retrospectively the diagnostic yield of various interventions in 84 elderly patients with new-onset seizures. Standard EEG was abnormal in 73 percent and CT, abnormal in 68 percent. MRI was performed in only 11 patients and was abnormal in 7. Dam, Fuglsang-Frederiksen, Svarre-Olsen, et al. (1985) studied different etiologies in 84 patients with new late-onset epilepsy. They reported that EEG was abnormal in 56 percent and CT was abnormal in 60 percent. However, only 7 of the 84 patients had unilateral signs on physical examination, but of these, 6 had focal findings on CT scan. Kilpatrick, Tress, O'Donnell, et al. (1991) reported on 50 patients with late-onset epilepsy with normal or nondiagnostic CT scans. MRIs within 3 months revealed diagnostic abnormalities in 10 of these patients. Luhdorf, Jensen, and Plesner (1986) studied prognostic factors in the elderly for 12 months after a first seizure. History did not correlate either to the type of seizure or to the presumed cause. A paroxysmal EEG, however, did. Lee (1985) studied ictal confusion as a first presentation of epilepsy in later life in 11 patients. Again, the history was not useful in diagnosis, but a standard EEG did result in a diagnosis in 5 of 11 patients.

One retrospective study assessed features of typical absence seizures. Panayiotopoulos, Chroni, Daskalopoulos (1992) noted that in all of 23 adults studied, events were documented in standard ± video EEGs (performed in 12). All 23 patients had normal neurologic and mental status.

Diagnosis of juvenile myoclonic epilepsy (JME) was the focus in four studies. Atakli, Sozuer, Atay, et al. (1998) reported that in a retrospective series of 76 patients with JME, a complete history led to a correct diagnosis in all 76, although 40 had presented with a misdiagnosis. In all patients, the neurologic examination was normal; and in 69 of 76 standard EEGs, background activity was normal. CT (in 32) and MRI (in 3) did not contribute to the diagnosis. Grunewald, Chroni, and Panayiotopoulos (1992) reported an average delay in the diagnosis of JME of 14.5 years; yet in all 15 children studied retrospectively, the diagnosis was made by history and standard EEG alone. In 14 of 15 patients, a misdiagnosis had been made originally. Panayiotopoulos, Tahan, and Obeid (1991) reported that the history and EEG alone were diagnostic in a retrospective series of 70 patients with JME. In 22 of these patients, a misdiagnosis had been originally made. Sharpe and Buchanan (1995) also reported a retrospective series of JME patients in whom diagnosis had been delayed for an average of 9.7 years. The history and CT were normal in all, and the value of the standard EEG in diagnosis had been reduced by the use of AEDs.

The new diagnosis of temporal lobe epilepsy was reported by Harvey, Berkovic, Wrennall, et al. (1997) in a retrospective series of 63 children. The neurologic examination was abnormal in 9, and the neuropsychiatric examination was abnormal in 24. Fewer than one-fourth of CTs (performed in 48) were abnormal, but nearly one-half of MRIs (performed in 58) were abnormal. Video EEG had a high yield in selected patients, with 18 of 20 revealing ictal activity.

Henneman, DeRoos, and Lewis (1994) reported an emergency room (ER) study of adults presenting with new-onset seizures. Of 333 seizure patients assessed in the ER, the clinical examination was clearly abnormal in 75 and routine blood tests were abnormal in 48. In 227 patients undergoing a lumbar puncture (LP), it was abnormal in <10 percent. Of 325 patients having a CT scan, a clinically significant abnormality was seen in about 40 percent. The standard ER workup consisted of a clinical examination, routine blood tests, and LP and CT in selected patients. The authors concluded that only 136 of the 254 patients admitted to hospital actually needed admission. Of these 136, the vast majority (129) were identified by a standard ER workup.

ILAE criteria for diagnosis were studied in two retrospective series. In Jallon, Goumaz, Haenggeli, et al. (1997), despite ILAE-determined epilepsy diagnoses in 273 patients, the standard EEG was normal in 67. In 190 of these patients, a CT was performed and was normal in 61. In 56 patients, a MRI was performed and was normal in 17. Reutens, and Berkovic (1995) assessed agreement of ILAE criteria with clinical features in 101 patients. In particular, not all patients fit ILAE syndromic diagnoses, and they reported phenotypic overlap between syndromes in adolescent generalized epilepsy.

In summary, the literature supports the diagnostic role of a complete history, especially in diagnosing JME, to elucidate an adequate description of the seizures to permit categorizing by seizure type, since a history suggestive of a focal seizure predicts recurrence. A clinical examination that includes a careful neurologic examination is essential, since an abnormal examination after a first seizure also predicts recurrence. The chance of recurrence is critical to decisions about initiating AEDs. Data are insufficient to conclude whether any blood tests at the time of a first seizure are useful except to rule out the presence of any secondary causes of seizures. As for standard EEGs, the literature suggests that it is an absolute requirement and should be performed as early as possible after the first seizure. The evidence reviewed does not permit conclusions about sleep EEGs or sleep-deprived EEGs. The studies in this review reported that only about 50 to 60 percent of standard EEGs are abnormal, but if the standard EEGs are performed within 24 hours of the first seizure, it is suggested that the diagnostic yield increases. Another reason to perform the standard EEG as soon as possible is the confounding influence of AEDs if started prior to diagnosis, which occurred in this literature in from 2 to 20 percent of patients. The role of MRI in first diagnosis is best established in late-onset seizure patients with nondiagnostic CTs, although other roles for MRI, such as in localization of seizure foci in operative candidates, have not been addressed in this review. The literature suggests that ambulatory and video EEGs are useful in a first diagnosis if standard EEG, CT, and MRI are nondiagnostic. Video EEGs are also useful in diagnosis in very young children, in patients with poorly characterized seizure types, and in those with suspected psychogenic seizures, especially if episodes are frequent.

### Monitoring

Evidences Tables 6, 6a, 7, and 7a display selected results of studies with monitoring information. None of these studies had as a primary objective the testing of monitoring interventions necessary for optimal patient care. There were 24 prospective interventional studies (8 RCTs, 7 nRCTs, 5 UCS, and 4 XS) that had a monitoring component, but in nearly all, this was a monitoring intervention dictated by a research study protocol and not optimal patient care. None of these studies enrolled patients after a first seizure but rather, on first presentation or first diagnosis.

The interventions covered included periodic drug levels and hematology and chemistry panels for the most part. Other interventions used in monitoring new patients after initiation of treatment with AEDs included measures of cognitive function and behavior (Camfield, Camfield, Dooley, et al., 1985; Frost, Hrachovy, Glaze, et al., 1995; Isojarvi, Parkarinen, and Myllyla, 1993; Kalviainen, Aikia, Helkala, et al., 1992; Mandelbaum and Burack, 1997; O'Dougherty, Wright, Cox, et al., 1987; Pulliainen and Jokelainen, 1994; Williams, Bates, Griebel, et al., 1998); EEG changes (Camfield, Camfield, Smith et al., 1985b; Drake, Weate, Newell, et al., 1994; Frost, Hrachovy, Glaze, et al., 1995; Konishi, Naganuma, Hongou, et al., 1995; Marciani, Maschio, Spanedda, et al., 1995; Sannita, Gervasio, and Zagnoni, 1989), median nerve evoked potentials (Carenini, Bottacchi, Camerlingo, et al., 1988), peripheral benzodiazepine receptor density (Ferrarese, Tortorella, Bogliun, et al., 1997), and QoL (Steiner, Dellaportas, Findley, et al., 1999).

Only the study by Camfield, Camfield, Smith et al., (1985b) could be considered as showing monitoring interventions that impact optimal patient care. In this study of standard EEG and neuropsychological changes with long-term use of AEDs in 82 children, behaviorial side effects or allergies led to treatment change in 11 patients and hematologic abnormalities led to change in 2. Another study (Sannita, Gervasio, Zagnoni, 1989) of 10 children, showed that EEG results did not relate to AED levels or to behavioral side effects, suggesting no role for EEG in routine monitoring of patients. The lack of relationship of EEG monitoring results to clinical seizure frequency in treated patients was also suggested by the results of the Drake study of spectral analysis of EEGs in 30 adults with new epilepsy after AED monotherapy. Although 25 patients demonstrated nocturnal sleep EEG abnormalities, none had seizures on treatment. There are several other studies in this review wherein standard EEGs were applied, all at highly variable intervals, ranging from every month (for the first 3 months) in one, to every 3, or 6, or 8 months in others, to once before AED withdrawal in one. None of these studies reported any effect of such monitoring on seizure frequency, dropout rates from AED side effects, or noncompliance. Furthermore, there were no studies reporting any change in quality of life or change in diagnosis or treatment as a result of standard EEGs performed as part of patient monitoring.

Monitoring cognitive effects of AEDs were the subject of several studies, with inconsistent results. Williams, Bates, Griebel, et al. (1998) showed no difference in cognitive or behavioral effects before and after treatment in 35 of 37 children initiated on AED monotherapy. On the other hand, Gunduz, Demirbilek, and Korkmaz (1999) reported that, in 20 newly treated children after 1 year, neurological dysfunction was detected on a battery of tests. In addition, Frost, Hrachovy, Glaze (1995) reported that language and Wechsler Intelligence Scale for Children (WISC)-derived measures declined at 1 year of AED treatment in 16 children. These studies could be interpreted as suggesting that monitoring of cognitive and neuropsychological measures may detect changes with long-term AEDs, especially in children. O'Dougherty, Wright, Cox, et al. (1987), however, reported that neuropsychological test results in 11 children did not necessarily correlate with AED drug levels.

Standard drug levels were measured "regularly" or "periodically" in followup in numerous studies, but the test frequency either was typically not specified or variable. There were no studies directly linking monitoring of standard drug levels to seizure frequency, dropout rates from AED side effects, or noncompliance. There were no studies reporting of any change in quality of life or change in diagnosis as a result of monitoring using standard drug levels. One interventional study, however, reported a change in treatment as a result of drug levels in 19 percent of monitored patients (Callaghan, Kenny, O'Neill, et al., 1985). Luhdorf, Jensen, and Plesner (1986) reported that subtherapeutic drug levels in a population of elderly patients with new epilepsy predicted recurrence.

As for periodic chemistries and/or hematology measures, one interventional study (Stefan, Plouin, Fichsel, et al., 1988) reported an increase in dropouts with adverse effects in 2 of 10 patients as a result of blood testing. The paper by Steiner, Dellaportas, Findley, et al. (1999) further supported the notion that understanding the distinctive side effects of different AEDs is important to optimal patient monitoring. In 181 patients with newly diagnosed epilepsy enrolled on a RCT comparing efficacy and tolerability of phenytoin and lamotrigine, abnormalities of liver enzymes occurred more often in the phenytoin patients, whereas abnormal elevations in serum creatinine were seen more often in the lamotrigine patients.

Chen, Mitchell, Horton, et al. (1995) reported on the use of video EEG in diagnosis and subsequent treatment decisions. It was performed once at entry and once in followup. One-fourth of all children had a diagnosis changed as a result of video EEG, and 88 percent of a subgroup referred especially for seizure classification were successfully diagnosed. The procedure was also useful to assist in preoperative assessment of surgical candidates. These results suggest a place for video EEG in new patients not readily classified or those who may be judged to be candidates for surgery.

In summary, the evidence, although scant, suggests there is no role for standard EEG in routine monitoring of patients after a new diagnosis of epilepsy. Video EEG has a role subsequent to a new diagnosis if the diagnosis is or becomes uncertain or if surgery is considered. Neuropsychological monitoring for behavioral and cognitive changes may have a role in identifying subtle AED side effects, especially in children. Blood testing (hematology and chemistries) is important to monitor for infrequent but potentially serious side effects of AEDs. Periodic drug levels may be important in assessing AED compliance, although this remains controversial. Since there is evidence that different AEDs impact QoL differently, there may also be a role for QoL monitoring.

### Treatment

Evidence Tables 8, 8a, 9, and 9a summarize selected results of studies with treatment information. Monotherapy AED as a treatment intervention was reported in over one-half the studies in the review for durations ranging from 2 weeks to 6 years. Monotherapy was a treatment intervention in 5 studies of patients at time of first presentation, 44 studies at first diagnosis, and 6 studies at first seizure. Monotherapy was associated with a report of remission of seizures in 56 to 75 percent of these patients, with lower rates in observational studies of real-world patients, mostly with a mixture of seizure types or epilepsy diagnoses. Rates of remission (seizure freedom) in general in newly diagnosed patients begun on AED monotherapy decrease over time, with 60 to 90 percent of patients in remission at 1 year, 30 to 60 percent at 2 years, and approximately 30 percent at 3 years. Patients are not "cured," but these studies suggest that seizure freedom for prolonged periods is possible with AED monotherapy. In most of these studies, there was no apparent difference in efficacy of AEDs. Only the side effect profiles of AEDs differed.

Polytherapy AED as a treatment intervention was unusual in newly diagnosed patients. In the eight studies that included any newly diagnosed patients with AED polytherapy, the proportions of such patients were low, ranging from 14 percent and 20 percent of all. One very small study (Penry, Dean, and Riela, 1989) reported a remission rate in six children on polytherapy (50 percent at 1 year). One interventional study of 622 adults at a Veterans Administration hospital (Smith, Mattson, Cramer, et al., 1987) reported a remission rate of 45 percent in newly diagnosed patients (n) receiving AED polytherapy (n=122) after first failing monotherapy. No studies reported dropout rates from side effects or from noncompliance or alterations in QoL associated with AED polytherapy.

In 15 studies, patients received no treatment: 8 after a first seizure, 2 at the time of a new diagnosis of epilepsy, 1 at first presentation, and 4 observational studies with "time zero" of diagnosis in the observation window. The durations within which patients remained with no treatment ranged from 2 weeks to 5.8 years. Remission rates with no treatment were highly variable; and given the many differences in patients across these studies, no conclusions can be drawn. These studies do underscore the fact, however, that some patients will do well without treatment. The difficulty is in identifying them.

Last, several studies were categorized as clinical/pharmacologic expertise studies. Clinical/pharmacologic expertise was defined as that expertise necessary for: (a) selecting optimal AEDs based on epilepsy diagnosis and patient characteristics, (b) adjusting drugs and dosages to reduce seizures, (c) monitoring and limiting adverse drug reactions and interactions, (d) monitoring patients' tolerance and compliance with particular drug regimens, (e) recognizing changes in seizure characteristics, and (f) ordering and interpreting appropriate laboratory tests based on knowledge of specific adverse events associated with different drugs. This was associated with epilepsy centers in 27 studies. In Atakli, Sozuer, Atay, et al., (1998), 35 of 40 misdiagnosed patients had, after correction of the diagnosis in an epilepsy center, their medications changed and became seizure free. In Grunewald, Chroni, and Panayiotopoulos (1992), inappropriate AEDs had been prescribed in 7 of 15 children prior to presentation to an epilepsy center. Furthermore, in Oller-Daurella and Oller (1991), a hospital-based study of adults, a shorter first seizure to treatment interval was associated with better remission durations, thus demonstrating that the timing of a correct diagnosis and treatment is also important to optimal patient management. There is considerable evidence for certain conditions, e.g., JME, that suggests that diagnosis and AED choice requires expertise. Seizure remission rates in studies categorized as clinical/pharmacologic expertise studies were high: in three observational studies, 79 percent of patients achieved remission, as did 84 percent of patients in the three interventional trials in this category.

There were no interventional or observational studies of any of the following treatment interventions: counseling, speech therapy, occupational therapy, physical therapy, education, or surgery in newly diagnosed patients.

In summary, the evidence supports the notion that optimal patient care would include access to health care professionals who are experts in the choice and timing of initial AED monotherapy, but it does not describe the training or experience of such caregivers. The shorter the interval from first seizure to diagnosis and initiation of treatment, the better. Although most studies reporting remission rates reported results ranging from 35 to 60 percent, the highest remission rates (79 to 84 percent) were reported in studies categorized with clinical/pharmacologic expertise. There is some evidence suggesting that clinical/pharmacologic expertise minimizes misdiagnoses, with resulting mistakes in choosing AEDs.

Optimal outcomes (Evidence Tables 10 and 10a) were explicitly or implicitly defined in terms of seizure frequency in 15 observational and 26 interventional studies. Interestingly, an optimal outcome was always defined as no seizures, but the requisite time period to maintain that goal varied widely (<3 months up to 2 years), suggesting lack of consensus as to what is an optimal outcome for newly diagnosed patients. Far less often (Aikia, Kalviainen, Sivenius, et al., 1992; Camfield, Camfield, Dooley, et al., 1985; Kalviainen, Aikia, Saukkonen, et al., 1995), the occurrence of a stipulated number of side effects was also reported as part of a definition of an optimal outcome. In all three studies that included side effects in the definition of "optimal," the optimal number of side effects was zero. Compliance, QoL, and costs were never noted as components of a definition of optimal patient outcomes.

## Key Questions

1. What elements (expertise, services, and tests) may be needed to make the first diagnosis and initiate and monitor optimal treatment? For the following tests (EEG -- standard, ambulatory, video, invasive; CT; MRI; lumbar puncture; blood tests), what is the cumulative contribution (in order of increasing invasiveness and cost) of each of the interventions to the accurate diagnosis of patients presenting with a first diagnosis?

This question needs to be considered in terms of whether it is after the first seizure or after the first epilepsy diagnosis, which requires at least two seizures in most diagnostic systems. Unfortunately, results of specific tests were reported quantitatively too infrequently to permit a quantitative assessment of cumulative contribution to accurate diagnosis.

However, the literature suggests, several factors predictive of prognosis which can be used to make a first diagnosis and treatment decision. There are 21 studies in the database (Evidence Table 11) that stated as a primary objective the purpose of assessing the predictive ability of various interventions and/or clinical signs and symptoms. Although there are a few notable exceptions, these reports typically represent observational studies of populations of patients of all ages and both genders with both generalized and partial seizures who are receiving AED therapy and followed for several years. These studies each assessed a different set of predictive factors, mostly after first diagnosis. Only 3 of the following reports were in cohorts followed after the first seizure (Hauser, Rich, Annegers, et al., 1990; Luhdorf, Jensen, and Plesner, 1986; Shinnar, Berg, Moshe, et al., 1996).

The factors that appear to be consistently associated with an increased risk of recurrence are the presence of remote symptomology (Aikia, Kalviainen, Mervaala, et al., 1999; Hauser, Rich, Annegers, et al., 1990; Shinnar, Berg, Moshe, et al., 1996), and the seizure frequency or type (partial has worse prognosis) (Aikia, Kalviainen, Mervaala, et al., 1999; Arts, Geerts, Brouwer, et al., 1999; Camfield, Camfield, Dooley, et al., 1985a; Camfield, Camfield, Smith et al., 1985b; Casetta, Granieri, Monetti, et al., 1999; Cockerell, Johnson, Sander, et al., 1997; Holt-Seitz, Wirrell, and Sundaram, 1999). Patient age at first seizure was predictive in three studies (Aikia, Kalviainen, Mervaala, et al., 1999; Casetta, Granieri, Monetti, et al., 1999; Cockerall, Johnson, Sander, et al., 1997). A family history of epilepsy denoted increased risk in only one of these studies (Hauser, Rich Annegers, et al., 1990). An abnormal interictal EEG (paroxysmal) was found predictive in four studies (Camfield, Camfield, Smith et al., 1985b; Hauser, Rich, Annegers, et al., 1990; Holt-Seitz, Wirrell, and Sundaram, 1999; Luhdorf, Jensen, and Plesner, 1986). An abnormal neuropsychiatric examination denoted increased risk in two studies (Aikia, Kalviainen, Mervaala, et al., 1999; Camfield, Camfield, Dooley, et al., 1985a). An abnormal MRI examination (i.e., the presence of hippocampal sclerosis) was associated with an increased risk of intractability in one study (Van Paesschen, Duncan, Stevens, et al., 1997). The lack of more studies reporting imaging abnormalities (either CT or MRI) is probably because most studies in this database targeted patients with idiopathic or cryptogenic epilepsy. Patients with tumors, strokes, and central nervous system (CNS) infections were typically excluded at the outset. The type of AED was found not to be a predictive factor for recurrence in four studies (Camfield, Camfield, Dooley, et al., 1985a, retrospective; Camfield, Camfield, Smith et al., 1985b, prospective; Casetta, Granieri, Monetti, et al., 1999; Hauser, Rich Annegers, et al., 1990). One study found that subtherapeutic blood levels of AED were predictive of recurrence, regardless of type of AED (Luhdorf, Jensen and Plesner, 1986), yet in another study, drug levels made no difference with regard to recurrence (Camfield, Camfield, Smith et al., 1985 - prospective). Discontinuation of AEDs (patient noncompliance) was associated with an increased risk in one study (Holt-Seitz, Wirrell, and Sundaram, 1999).

Two studies assessed recurrence risk in treated and untreated patients. Shinnar, Berg, Moshe, et al., (1996) reported on 407 children after a first unprovoked seizure (i.e., not yet with a diagnosis of epilepsy) and found no difference in recurrence whether they were treated with AEDs or not -- 69 percent of recurrences happened in the first 6 months, and the median time to recurrence was 5.7 months. Camfield, Camfield, Dooley, et al., (1985a - retrospective), however, reported in a study of 168 children with a first diagnosis that 55 percent on AEDs recurred and 45 percent of untreated patients recurred. Given this was a retrospective observational study, the influence of patient factors on decisions to treat was not measured. Recurrence with and without treatment is therefore uninterpretable because of possible patient selection bias.

- What is the positive and negative predictive value of each test alone? There are insufficient data to answer this question.
- In what instances do additional tests add little useful information? Is there evidence that not applying particular tests will lead to incorrect diagnosis, negative health, or negative psychosocial outcomes? Are these tests useful for all patients undergoing first diagnosis or for only particular subpopulations? Which components of the patient's history are necessary to accurately diagnosis the first seizure?

The core elements of a workup for patients not yet diagnosed include a complete history, focusing on details that are likely not only to permit a correct diagnosis of epilepsy, but also to predict an increased likelihood of recurrence. The chief elements in this category are remote symptomology, any clues to a secondary cause of seizures, and a detailed description of the seizures, including number prior to presentation. Details suggesting a focal component must be elicited. A physical examination including neuropsychiatric assessment as a component of the diagnostic workup is also supported by the evidence, in that abnormalities may be predictive of recurrence as well as indicate secondary causes of seizures. A standard EEG is necessary for diagnosis. The specific experience and training of providers required to successfully implement the diagnostic workup is not covered in this literature, although the value of clinical/pharmacologic expertise is supported.

Absence seizures are diagnosed by a characteristic history and EEG. In patients with JME, the diagnosis is established by a suggestive history with a normal EEG. In the elderly with new seizures, a CT and EEG are more often abnormal than in younger patients presenting with seizures. In newly diagnosed patients, video EEG is useful in the very young and in those with poorly described and frequent events.

The use of additional tests remains discretionary as measures to rule out clinically suspected secondary causes of seizures, such as tumor, infection, or stroke. These examinations will be unlikely to provide additional information with regard to a diagnosis of epilepsy per se.

Except for video EEG, there is no evidence in the published literature to suggest that not applying the additional tests noted above will lead to an incorrect diagnosis or negative health or psychosocial outcomes. This falls into the realm of common sense medical wisdom, but without literature support.

2. What criteria should be used to guide decisions regarding the timing and selection of treatments for patients undergoing first diagnosis?

The core elements described above for Question 1 are the criteria that should be used to guide decisions regarding timing and selection of treatments in newly diagnosed patients. Patients judged to have a low likelihood of seizure recurrence on the basis of the results of the core workup may well be followed after a first seizure without initiating AEDs. These would include patients in whom no secondary causes of seizures are likely (e.g., no tumors, strokes, infections, etc.) and with no remote symptomology, no sign of focality in the description of the seizures, only one seizure prior to presentation, a completely normal general and neuropsychiatric examination, and a normal interictal EEG. Should a second seizure occur, a decision to initiate AEDs would need to be reconsidered.

As for the selection of treatments, there is no convincing published evidence that one AED is more efficacious than another for most, but not all, epilepsy syndromes. Monotherapy, as opposed to drug combinations, is generally utilized as a first option in the literature. Side effect profiles (reasonably well supported in the literature), QoL (poorly supported in the literature), and costs (poorly supported in the literature) may all inform choice of AEDs. Also, special population issues, such as women's issues, especially with regard to AED teratogenicity, may influence AED decisions. Since the predictive models cited above also show that noncompliance with AEDs is associated with an increased risk of recurrence, consideration of the particular features of the plethora of old and new AEDs, as well as patient support services that are likely to improve compliance, are important considerations in AED choice.

3. Which interventions are necessary to adequately monitor patients on their first epileptic drug regimen to ensure that the first diagnosis was correct? For what period of time should this monitoring occur? Should such monitoring be routine or prompted by particular symptoms/events?

The scarcity of the literature on the subject of patient monitoring does not permit conclusions about the necessary and appropriate interventions for patients on their first AED. A role for blood test monitoring for the occurrence of both predictable and idiosyncratic hematologic and chemical abnormalities is supported. These side effects (e.g., aplastic anemia or liver enzyme elevation) are different for each AED and may not be expected to occur in the relatively small populations and short observation intervals typical of studies in the published literature. This evidence base could be enhanced by including literature broader than just studies of newly diagnosed patients. Yet, even if we were to include all relevant literature, the occurrence of extremely rare, but severe side effects, may still not be detected. Programs for monitoring real-world patients in large, long-term postmarketing surveillance studies would be needed and would supplement other forms of surveillance, such as the Food and Drug Administration MedWatch program.

Given the evidence cited above that compliance with AEDs may be an important predictor of successful control of seizures, interventions designed to ensure compliance are also important. The compliance measure noted in the literature most often was the performance of standard drug levels. As a compliance measure, this is controversial. Furthermore, there is little consistent evidence to support an association between therapeutic drug levels and seizure control, with some reports suggesting control is unrelated to drug levels and others suggesting it is related. Pill counting as a measure of compliance has been employed in only a few of the studies in this database, and its merit relative to drug levels, or patient diaries, has not been substantiated.

The role of standard EEG in monitoring after diagnosis, such as at the time of consideration of AED withdrawal, is not the subject of this report. The role of video and ambulatory EEG is confined to refining or changing an uncertain diagnosis or in preoperative evaluations for seizure surgery. When seizures are frequent and features are atypical or uncertain, these EEGs may well contribute information necessary to correct a misdiagnosis. The literature describing these EEGs appears confined to specialists in academic centers.

Evidence also supports the role of cognitive and behavioral testing in monitoring children on long-term AEDs. Furthermore, since the literature suggests that QoL may differ according to AED type and with the increasing focus in medicine on patient-centered outcomes, it would seem appropriate to monitor simply, but formally, in newly diagnosed patients after AED initiation.

The evidence does not provide a finite period of time in which monitoring of newly diagnosed patients should occur. Nor is there a consistent approach to the frequency of routine monitoring interventions supported by the literature. Most routine monitoring visits and standard drug levels applied to patients on studies in the literature occurred at 3- to 6-month intervals initially and then at increased intervals in subsequent years. There is nothing in the literature addressing which changes in patient status should prompt a nonroutine monitoring visit. Choice of necessary and appropriate monitoring, both routine and prompted, thus remains in the realm of medical practice, largely unsupported by the literature.

4. What aspects of clinical/pharmacologic expertise have been demonstrated to result in optimal patient outcomes (maximum reduction of seizure frequency with minimal side effects)?

Presently, it should be recognized that the definition of optimal patient outcomes is unidimensional in the literature. The single dimension is seizures. The optimal number is generally considered to be zero, but the minimum interval of time in which no seizures should occur is surprisingly variable, ranging from a few weeks to several years. Side effects, health care utilization, or costs are not a dimension of most definitions of optimal outcomes. QoL also was not a feature of optimal outcomes in any studies, and only two studies used a specific instrument. Readers may find more QoL information in recent reviews (Devinsky, Vickrey, Cramer, et al., 1995, Kline Leidy, Rentz, and Grace, 1998).

Clinical/pharmacologic expertise was defined as that expertise necessary for: (a) selecting optimal AEDs based on epilepsy diagnosis and patient characteristics, (b) adjusting drugs and dosages to reduce seizures, (c) monitoring and limiting adverse drug reactions and interactions, (d) monitoring patients' tolerance and compliance with particular drug regimens, (e) recognizing changes in seizure characteristics, and (f) ordering and interpreting appropriate laboratory tests based on knowledge of specific adverse events associated with different drugs. Also, appreciation of special issues of tailoring AEDs to specific patients, such as women of childbearing age, may be considered as part of clinical/pharmacologic expertise.

Since the nature and degree of experience and training necessary to obtain clinical/ pharmacologic expertise was not addressed in this literature, conclusions are not warranted as to which caregivers might have such expertise. Also, since few studies were led by primary care practitioners, there is a possible bias in these studies suggesting academic neurologists as the sole source of clinical/pharmacologic expertise. As in many other areas of medical practice, including cardiovascular interventions, surgical procedures, and cancer care, expertise and improved patient outcomes may be associated with increased volume of patients cared for. Since there are no studies in this review to prove such an association, we can only hypothesize that volume of practice may be a surrogate for both clinical/pharmacologic expertise and improved patient outcomes.

5. What is necessary for patients at the time of first diagnosis in terms of social services, counseling (regarding, for example, employment or driving), or assistance and information from the Epilepsy Foundation? Is there evidence demonstrating that counseling improves patient followup, compliance, or quality of life?

There is virtually nothing in this literature that speaks to the impact in newly diagnosed patients of either counseling or assistance from groups such as the Epilepsy Foundation. No literature demonstrates that counseling improves patient followup, compliance, or quality of life. The one study that touches on these issues is by McNelis, Musick, Austin, et al. (1998) which surveyed families of 63 children over 6 months from the time of a first seizure. They report that 17 to 38 percent were not satisfied with their health care at 6 months. Also, 41 to 74 percent of those interviewed reported they needed more information, and 24 to 65 percent needed support services. Although the evidence from only one study is sparse, it suggests an unmet need in the provision of health care services to these patients. The dearth of studies in the literature on this subject suggests a lack of research interest in this topic.

## Limitations and Strengths of the Evidence Base

This systematic review has highlighted the many limitations of the literature addressing issues relevant to patients with newly diagnosed epilepsy. There are huge gaps in coverage of important topics, particularly diagnostic and monitoring interventions, and patient-centered and/or optimal outcomes. There is relatively little primary research in newly diagnosed patients, as evidenced by the enormous study attrition from the original search numbers (>13,000 citations) to the number of studies fully eligible for review (120). It is tempting to speculate in this, as in any body of literature, that the number of narrative reviews, commentaries, opinions, and anecdotal case reports is inversely proportional to the volume and rigor of the primary research in the field. Even among the studies that were eligible for inclusion in this review, the average evidence score was in the bottom 20 percent of possible scores. Among eligible studies, incomplete reporting was the rule rather than the exception. For example, in 42 studies with a diagnostic focus, sensitivity and specificity were present in only three.

Although a gold standard for epilepsy diagnosis has been lacking, a common standard based on basic clinical and EEG features is possible and should be used in all research studies. The literature is further weakened by basic term confusion: epilepsy and seizures are often used interchangeably. This makes it difficult to clearly separate evaluations of first seizures from epilepsy per se, which is critical, since the assessment and prognosis in each setting are quite different. With regard to seizure type, few studies described patterns of seizure onset to distinguish generalized from focal seizures. Furthermore, old epilepsy classification schemes are used, or none at all. Even "newly diagnosed" has many meanings in this literature. Although we have included studies of patients with first seizure, first presentation, and first diagnosis in this review, we are the first to acknowledge that these patients are not exactly equivalent. Patient populations are also not clearly defined with regard to primary (idiopathic) or secondary causes (e.g., tumors). How can we interpret and/or generalize any of the outcomes from such mixed population studies? Furthermore, this literature is not likely to be representative of the experience of most patients and most treating physicians, as this literature is derived mostly from academic hospital settings and is mostly from Europe. How should these results be generalized to the United States, where medical practice and patient demographics are likely to be quite different and much more variable?

The chief limitation of the review process, rather than the literature itself, is the fact that identifying studies relevant to the original questions was so difficult. Judgment calls were required uncomfortably often. We are cognizant of the potential criticism that we excluded potentially relevant studies. These include studies of patients without epilepsy, but with conditions that might pose obstacles to correct diagnosis, such as studies limited to patients with psychogenic seizures or pseudoseizures. Also, as noted previously, we excluded studies specifically addressing diagnostic interventions made after an original diagnosis and intended to correct a misdiagnosis or to refine an uncertain diagnosis. These studies are of interest but were judged tangential to the main focus of this review. We strove to define newly diagnosed patients more narrowly than others might in order to keep patient populations in the final database as comparable as possible.

A further limitation is that information about how to manage newly diagnosed patients does not often come from published studies. For example, since AED pharmacokinetic data is not typically generated in newly diagnosed patients, what is its applicability to this population? Also, it is widely accepted that blood monitoring needs to be done for specific AEDs to monitor for rare idiosyncratic events. This is known from evaluating hundreds of thousands of real-world patients, not just the thousands who are represented in the published literature. Literature alone cannot be used to support criteria for optimal patient management.

Despite these limitations, this evidence base should be considered as representing the best available evidence at this time. The patients represented include adults, children, and the elderly, men and women. A substantial proportion of this literature represents observational reports from real-world settings. Multiple stakeholders have had a voice in this review. It is a systematic, comprehensive, and current snapshot of a literature that is evolving. It is now organized in such as way as to be updatable and expandable to include other data elements or other patient populations of interest. Lastly, the approach to developing a matrix framework of patients and services, with a systematic review of the evidence addressing each patient-service intersect of the matrix, provides a useful model for assessing health care services for other low-prevalence, highly chronic conditions.