# Introduction

In the care of patients with epilepsy, the ideal goal is "no seizures and no side effects equals control," as articulated by a clinical working group of the 1997 Living Well With Epilepsy Conference (Health 2000, 1998). For this goal to be achieved or approximated, there are three prerequisites: the prompt and accurate diagnosis of epilepsy in patients presenting with epileptic seizures, the administration of an appropriate first treatment intervention, and adequate monitoring to ensure not only the efficacy and safety of the treatment intervention but the accuracy of the initial epilepsy diagnosis. For these prerequisites to be met, appropriate and necessary health care services need to be available to patients at the right time. But what are appropriate and necessary health care services pertinent to the diagnosis, monitoring, and treatment of patients with newly diagnosed epilepsy? The purpose of this project was to assess the evidence in the published literature that might be used to answer this question.

In this Task Order, MetaWorks and collaborating investigators at the University of Pennsylvania have developed an evidence base via a systematic review of the literature published in English pertinent to diagnostic, treatment, and monitoring interventions in patients with newly diagnosed epilepsy. The topic "Criteria for Referral of Patients with Epilepsy" was nominated by the Centers for Disease Control and Prevention (CDC) to support its efforts to determine effective care for persons with epilepsy. Such criteria may be used as a framework for organizing the clinical processes necessary to provide optimal care for persons with epilepsy. Furthermore, the approach to developing a framework of care may provide a useful model for other low-prevalence, highly chronic conditions.

The project was carried out in two phases over an 18-month period, starting in October 1998. Phase I tasks were preparatory to a 1-day meeting in March 1999 of a multidisciplinary panel of stakeholders representing epileptology, neurology, primary care, nursing, health care systems, and consumers. The meeting resulted in a matrix framework of diagnostic, monitoring, and treatment services for five patient populations of interest: patients undergoing first diagnosis, patients demonstrating intractability, patients presenting with comorbidities, patients with side effects from antiepileptic drugs (AEDs), and patients withdrawing from AED therapy.

In Phase II, an initial assessment of the quantity of literature potentially available for each cell in the matrix (i.e., each patient/service intersect) was obtained. This work was described in the Work Plan dated May 24, 1999, with revision dated July 20, 1999. Questions regarding diagnosis, monitoring, and treatment services were then formulated to guide subsequent literature reviews in each patient population of interest. Stakeholder feedback was obtained to help prioritize the questions, populations, and services along several domains. A joint decision was made in October 1999 to pursue a systematic review of the literature to answer questions referable to one population (persons with a first diagnosis of epilepsy) across all of the health care service questions posed. This selection was made because it received the highest priority ratings from stakeholders, it appeared to have sufficient literature available, and the remaining contract budget was sufficient to cover the anticipated work.

Therefore, the primary objective of Phase II, of this project was to answer specific questions regarding diagnosis, monitoring, and treatment services needed by people with a first diagnosis of epilepsy. The following key questions were addressed in a systematic review of the literature:

1. What elements (expertise, services, and tests) may be needed to make the first diagnosis and initiate and monitor optimal treatment? For the following tests (electroencephalogram (EEG) -- standard, ambulatory, video, invasive; computed tomography (CT); magnetic resonance imaging (MRI); lumbar puncture; blood tests), what is the cumulative contribution (in order of increasing invasiveness and cost) of each of the interventions to the accurate diagnosis of patients presenting with a first diagnosis? What is the positive and negative predictive value of each test alone? In what instances do additional tests add little useful information? Is there evidence that not applying particular tests will lead to incorrect diagnosis, negative health, or negative psychosocial outcomes? Are these tests useful for all patients undergoing first diagnosis or only for particular subpopulations? Which components of the patient's history are necessary to accurately diagnose the first seizure?
2. What criteria should be used to guide decisions regarding the timing and selection of treatments for patients undergoing first diagnosis?
3. Which interventions are necessary to adequately monitor patients on their first epileptic drug regimen or to ensure that the first diagnosis was correct? For what period of time should this monitoring occur? Should such monitoring be routine or prompted by particular symptoms/events?
4. What aspects of clinical/pharmacologic expertise have been demonstrated to result in optimal patient outcomes (maximum reduction of seizure frequency with minimal side effects)? Clinical/pharmacologic expertise is defined as: (a) selection of optimal antiepileptic drugs based on epilepsy diagnosis and patient characteristics, (b) adjusting drugs and dosages to reduce seizures, (c) monitoring and limiting adverse drug reactions and interactions, (d) monitoring patients' tolerance and compliance with particular drug regimens, (e) recognizing changes in seizure characteristics, and (f) ordering and interpreting appropriate laboratory tests based on knowledge of specific adverse events associated with different drugs.
5. What is necessary for patients at the time of first diagnosis in terms of social services, counseling (regarding, for example, employment or driving), or assistance and information from the Epilepsy Foundation? Is there evidence demonstrating that counseling improves patient followup, compliance, or quality of life?

This Evidence Report may inform policy decisions regarding the organization of optimal clinical processes necessary to achieve the prompt and accurate first diagnosis of epilepsy.

## Background

Recent estimates of the incidence and prevalence of epilepsy vary geographically (Beilmann, Napa, Soot, et al. 1999, Kun, Ling, Wah, et al. 1999, Olafson and Hauser, 1999; Onsurbe Ramirez, Hernandez Rodriguez, Aparicio Meix, et al., 1999; Sawhney, Singh, Kaur, et al., 1999; Wiebe, Bellhouse, Fallahay, et al. 1999). The Global Burden of Disease Project, a collaborative study between the World Health Organization (WHO) and the Harvard School of Public Health, reports 1990 incidence and prevalence for both established market economies (EME) and formerly socialist economies (FSE) (Murray and Lopez, 1996). The incidence of epilepsy in EME is 0.06 percent in males and 0.07 percent in females. The incidence of epilepsy in FSE is 0.18 percent in males and 0.09 percent in females. The total incidence in EME is 0.06 percent and the total incidence in FSE is 0.13 percent in the general population. In 1990, the prevalence of epilepsy in EME was 0.59 percent and in FSE, 0.75 percent, in the population (Murray and Lopez, 1996).

The early diagnosis of epilepsy is challenging because seizures are a common symptom of many disease states (Sander, Hart, Johnson, et al., 1990). Misinterpretation of signs, symptoms, and history may lead to lengthy delays in diagnosis (Forsgren, 1990). More commonly, the diagnosis of epilepsy and the subsequent classification of seizure type is complicated by uncertainty about the appropriate selection and interpretation of various diagnostic tools such as EEGs, CTs, and MRIs (Grabow 1985, King, Newton, Jackson, et al., 1998). Particular diagnostic and monitoring resources such as video EEG are costly but may be of variable utility in the diagnosis of epilepsy (Chen, Mitchell, Horton, et al., 1995, Foley, Legido, Miles, et al., 1995). It may be possible, however, to identify particular patient characteristics, such as high paroxysmal event frequency, that warrant the use of expensive or invasive diagnostic and monitoring resources (Mohan, Markand, and Salanova, 1996). The timing of when a patient seeks medical attention following a paroxysmal event may also be a key variable in differentiating the utility of particular diagnostic interventions (King, Newton, Jackson, et al., 1998). Notably, the promptness with which the diagnosis of epilepsy is achieved may directly impact treatment decisions. It has been debated, for example, whether the administration of antiepileptic drug therapy is justified before a definitive diagnosis of epilepsy is achieved (Caplan, 1994).

Incorrect diagnosis or seizure classification may lead to an inappropriate choice of antiepileptic drugs and therefore poor response to treatment (Chen, Mitchell, Horton, et al., 1995). Relapse of seizures for patients on treatment is common and has been estimated to be as high as 52 percent in some populations (Beghi and Tognoni 1988; Hopkins, Garmon, and Clarke, 1988). Frequent seizures may not only be associated with reduced quality of life and higher mortality but may also lead to higher total health care costs and resource utilization (Baker, Nashef, and van Hout, 1997). The latter is not insubstantial. A very recent study sponsored by the Epilepsy Foundation (Begley, Famulari, Annegers, et al., 2000) appeared subsequent to our literature search and suggests that the cost of epilepsy in the United States is $12.5 billion dollars.