# Appendix C. Acronyms

AED | antiepileptic drug
AHRQ | Agency for Healthcare Research and Quality
CDC | Centers for Disease Control and Prevention
CK | creatine kinase
CNS | central nervous system
CSF | cerebral spinal fluid
CT | computerized tomography
DEF | data extraction form
EEG | electroencephalogram
EME | established market economies
ER | emergency room
FSE | formerly socialist economies
ILAE | International League Against Epilepsy
JME | juvenile myoclonic epilepsy
LoE | Level of Evidence
LP | lumbar puncture
MeSH | Medical Subject Heading
MRI | magnetic resonance imaging
NPV | negative predictive value
nRCT | nonrandomized controlled trial
OT | occupational therapy
PET | positron emission tomography
PPV | positive predictive value
PT | physical therapy
QC | quality control
QoL | quality of life
RCT | randomized controlled trial
SEALS | Side Effects and Life Satisfaction Scale
TEP | technical experts panel
UCS | uncontrolled case series
VAS | visual analog scale
WISC | Wechsler Intelligence Scale for Children
XS | cross-sectional