# Appendix B. Technical Expert and Peer Review Panel

Technical Expert Panel

Panel Members | Specialty/Category | Affiliation
Gregory L. Barkley, M.D. | Epilepsy Specialist | Medical Director, Henry Ford Comprehensive Epilepsy Program, Detroit, MI
Joyce Bender | Consumer Advocate | Bender Consulting Services, Inc. Pittsburgh, Pennsylvania
Patricia Dean, MSN, MS | Epilepsy Specialist | Miami Children's Hospital Miami, Florida
Margaret Gunter, PhD | Health Services | Lovelace Clinic Foundation Albuquerque, New Mexico
Suzanne Mercure | Health Services | Institute for Health Policy Solutions Falls Church, Virginia
David Stumpf, M.D., PhD | Neurologist | Northwestern University Medical School, Chicago, Illinois
Louis Trost, M.D. | Primary Care | Lovelace Family Practice - Westside Albuquerque, New Mexico
Linda Warner | Consumer Advocate | Forest Lake, Minnesota

Peer Review Panel

Peer Review Panel | Specialty/Category | Affiliation
Javier Aceves, M.D. | Primary Care | Pediatrics - Lovelace Health Systems Rio Rancho, New Mexico
Claire Chee, RN | Pediatric Epilepsy Specialist | Current President of ACNN Children's Hospital of Philadelphia
Stephen Collins, M.D. | Industry Representative | Abbott
Patricia Crumrine, M.D. | Neurologist | Children's Hospital, Pittsburgh, PA. (Representing American Academy of Pediatrics)
Joseph D'Souza, PhD | Industry Representative | Novartis
John Gates, M.D. | Epilepsy specialist | Minnesota Epilepsy Group, St. Paul, Minnesota
Elizabeth Garofalo, M.D. | Neurologist, Industry Representative | Parke-Davis
Frank Gilliam, M.D., MPH | Epilepsy Specialist | Washington University School of Medicine, Dept. of Neurology - St. Louis, MO
Robert Gumnit, M.D. | Epilepsy Specialist | President, Nat'l Association of Epilepsy Centers MINCEP Epilepsy Care, Minneapolis, MN
Cynthia Joyce | Consumer Advocate | Director, Education and Research Foundation of the American Academy of Neurology
Allan Krumholz, M.D. | Epilepsy Specialist | Univ. of Maryland, Dept. of Neurology
Lisa Lindahl | Consumer Advocate | Spear-headed the Women's Initiative" for the Epilepsy Foundation.
Janet Mims, RN | Consumer Advocate | Past President of Assoc. of Child Neurology Nurses(ACNN)
Martha J. Morrell, M.D. | Epilepsy Specialist | Professor, New York Presbyterian Hosp. Chair, Epilepsy Foundation Board of Directors
Jay Rosenberg, M.D. | Neurologist | San Diego, CA
Steven Schachter, M.D. | Epilepsy Specialist | Beth Israel Deaconess Comprehensive Epilepsy Center, Chair, Epilepsy Foundation Professional Advisory Board.
Stephen Schwabe, M.D. | Industry Representative | Johnson & Johnson
Patricia Shafer, RN | Epilepsy Specialist | BI Deaconess Medical Center, Boston, MA Chair Elect, Epilepsy Foundation Professional Advisory Board
Kari Swarztrauber, M.D. | Neurologist | Post Doctoral Fellow - UCLA Dept of Neurology