# Appendix A. Data Extraction Form Patients Newly Diagnosed With Epilepsy

| Extractor/date_____________
| Consensor/date____________

Study Level Characteristics Author/Year___________/_____ Location (E, NA, Other__________) Total pts_______Healthy Ss?______ Design: Observational/Interventional Retro/Pro RCT/nRCT/UCS/XS ?Open Label Ext? Yes Evidence Score = Rand___+ Blind___+ WD ____= ____ or 1 / L o E _______ = ________ Study duration: max_______(mos) mean/median_______(mos) Accrual years ________ Classification system: ILAE '81, '89, other (___________), or NR Industry sponsor (yes_______________ or no/NR) Population: Adult Peds Both Costs? (yes/no) QOL? (yes/no): if yes, tool =_______________ Intervention Location? home, hospital, office/clinic, epilepsy center, academic, other, unknown or NR Usual epilepsy care provider id'd? 1° MD, IM, Neuro, Epil MD, surgeon, radiol., other, unknown or NR Investigator id'd? 1° MD, IM, Neuro, Epil MD, surgeon, radiol, academic, other, unknown or NR Pts on study at: 1st seizure/ 1st presentation/ 1st dx/ not 1st event, but T_0_ in observation window Inclusions: NS/specified: #seizures?___ in past? ____(mos, yrs) Unprovoked? Yes/ No / NR Exclusions for 2° causes: NS / specified? Yes/No (tumor, trauma, infection, stroke, etoh/drugs, neuro, pseudo, psycho, medical, febrile, inf. spasms) 1° study objective (Dx, Mx, Tx) & text:_________________________________________.

TOTAL | | Epilepsy Patients
Patients enrolled (#)
Age (mean/median) (range)
Race (C/AA/H/A/Other - #)
Gender (M/F - #)
Family history (#)
Seizure type: # general
# partial
#absence
#other
# on AEDs at entry
# history of AED use
Epilepsy Syndrome Dx
#% with
#% with
#% with
#% with
#% with
#% with

Diagnostic | Who ? | When? | Dx made? | Dx Δ? | Costs?.
History/Physical (D11)
Blood tests (D13)
Neuropsych (D8)
LP (D9)
CT (D10)
EEG std (D5)
MRI (D6)
PET/SPECT (D7)
EEG invasive (D1)
EEG video (D2)
EEG ambulatory (D3)
EEG other (D4)

Diagnostic | Gold Std*? | Sens | Spec | "R" | PPV | NPV | 2X2 | Other.
History/Physical (D11)
Blood tests (D13)
Neuropsych (D8)
LP (D9)
CT (D10)
EEG std (D5)
MRI (D6)
PET/SPECT (D7)
EEG invasive (D1)
EEG video (D2)
EEG ambulatory (D3)
EEG other (D4)

Gold standard = epilepsy defined as___________________________________________________________________ _______________________________________________

Incidence new epilepsy diagnoses total n =______; n per __________ = ______

Monitoring | Who ? | When? | Where? | Frequency? | Costs?
Pharm. Exp (M4)
Blood tests (M8)
Drug levels (std) (M7)
Drug levels (soph) (M6)
EEG std (M5)
EEG invasive (M1)
EEG video (M2)
EEG ambulatory (M3)
Other (M9)

Monitoring | Δseizure fr ↓↑[image] | ΔAED AEs ↓↑[image] | Δcompliance ↓↑[image] | ΔQoL ↓↑[image] | ΔDx ↓↑[image] | ΔRx ↓↑[image]
Pharm. Exp (M4)
Blood tests (M8)
Drug levels (std) (M7)
Drug levels (soph) (M6)
EEG std (M5)
EEG invasive (M1)
EEG video (M2)
EEG ambulatory (M3)
Other (M9)

Treatment | Who ? | When? | Where? | How long? | Costs?
No Rx (T9)
Drug studies (T2)
Drug Rx:Mono (T10)
Drug Rx: Poly (T11)
Pharm Exp. (T4)
Social services (T8)
Counsel ψ (T7)
Speech (T6)
OT/PT (T5)
Education (T3)
Surgery (T1)
Other (T12)

Treatment | Δ seizure frequency ↓↑[image] | rem/recur rate/risk ↓↑[image] | Δside effects ↓↑[image] | Δcompliance ↓↑[image] | ΔQoL ↓↑[image]
No Rx (T9)
Drug studies (T2)
Drug Rx:Mono (T10)
Drug Rx: Poly (T11)
Pharm Exp. (T4)
Social services (T8)
Counsel ψ (T7)
Speech (T6)
OT/PT (T5)
Education (T3)
Surgery (T1).
Other (T12)
Optimal outcomes defined? No/Yes: #/% unit in___duration with (code):
| Seizures.
| side effects.
| compliance.
| QoL.
| Costs.
Compliance measured by pill counts, drug levels, other____________________________________________