# Appendixes

Appendix A. Data Extraction Form Patients Newly Diagnosed With Epilepsy

Appendix B. Technical Expert and Peer Review Panel

Appendix C. Acronyms