# Acronyms and Abbreviations Used in the Evidence Tables

5-FU | 5-fluorouracil
AC | Anterior chamber
ACG | Angle closure glaucoma
ALT | Argon laser trabeculoplasty
ATT | Argon laser trabeculoplasty - trabeculectomy - trabeculectomy treatment sequence
BSS | Balanced salt solution
CE | Cataract extraction
CME | Cystoid macular edema
DSCI | Deep sclerectomy with collagen implant
ECCE | Extracapsular cataract extraction
Epi. | Corneal epithelial
Hem. | Hemorrhage
ICCE | Intracapsular cataract extraction
IOL | Intraocular lens
IOP | Intraocular pressure
MMC | Mitomycin-C
N/A | Not applicable
No CE | No cataract extraction
NR | Not reported
NRCT | Non-randomized controlled trial
OAG | Open-angle glaucoma
PC | Posterior capsule
PCO | Posterior capsular opacification
PECE | Phacoemulsification cataract extraction
Phaco. | Phacoemulsification
PMMA | poly(methyl methacrylate) intraocular lens
POAG | Primary open-angle glaucoma
RCT | Randomized controlled trial
SPK | Superficial punctate keratitis
TAT | Trabeculectomy - argon laser trabeculoplasty - trabeculectomy treatment sequence
Trab. | Trabeculectomy
VA | Visual acuity
YAG | YAG laser