# Evidence Tables

Evidence Table 1. Overall summary of the literature on treatment of coexisting cataract and glaucoma

Study Information (Author, Year; Location) | Study Design | Main Study Aim(s) | Number of Eyes Enrolled | Proportion of Patients | Mean Age | Principal Outcomes of Study | Mean Study Followup | Main Study Limitations | Overall Quality Score | Conclusion
Advanced Glaucoma Intervention Study, The, 1998 United States | RCT | To report separately for black and white patients with advanced glaucoma 7 year results of 2 alternative surgical intervention sequences. | 776 | 0.58 | NR | Acute IOP; Long-term IOP; Cataract | 24 months or longer | No masking | 70 | Data support the use of argon laser trabeculoplasty- trabeculectomy- trabeculectomy sequence for black patients, but trabeculectomy-argon laser trabeculoplasty- trabeculectomy sequence for white patients without life-threatening health problems.
Anand, Menage, Bailey, 1997 Europe | Cohort | To compare visual outcomes and complications among 3 methods of combined cataract and glaucoma surgery. | 132 | 0.00 | 78.7 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 6 to 11 months | Minimal or no inclusion/exclusion details; No masking; Important/unknown baseline differences; Little or no surgical details | 28 | No differences were seen in IOP control when comparing 1-site ECCE, 1-site phacoemulsification, and 2-site ECCE procedures. PCO requiring YAG was less common in the phacoemulsification group.
Anders, Pham, Holschbach et al., 1997 Europe | RCT | To determine if a radial incision could lead to a lasting decrease in IOP and the development of filtering blebs after combined phacoemulsification and filtering surgery versus cataract extraction alone. | 85 | NR | 76.5 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Minimal or no inclusion/exclusion details; No masking | 67 | The combined procedure lowered IOP, so did cataract surgery alone, but not as much.
Arnold, 1996 United States | Cohort | To compare glaucoma control in patients receiving no stitch phacoemulsification/ trabeculectomy versus patients receiving a 2 stitch phacoemulsification/ trabeculectomy. | 40 | NR | NR | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | NR | Baseline info poor; No masking; Important/unknown baseline differences | 37 | Similar results were obtained for group with no stitch compared to 2 stitch procedure. However, more postoperative complications were observed in the 2 stitch group. Due to design issues generalizeability of these results is limited.
Asamoto, Yablonski, 1993 United States | Clinical series | To determine if reforming the anterior chamber with air leads to higher rates of cataract after trabeculectomy. | 173 | 0.18 | 62.2 | Long-term IOP; Cataract; Complications | 24 months or longer | N/A | N/A | Intraoperative use of air to reform the anterior chamber in trabeculectomy is associated with significantly higher rates of anterior subcapsular cataract.
Bellucci, Perfetti, Babighian et al., 1997 Europe | Cohort | To compare trabeculectomy alone with phacoemulsification/trabeculectomy. | 300 | NR | 63.5 | Long-term IOP; Cataract; Complications | NR | Minimal or no inclusion/exclusion details; Important/unknown baseline differences; Differences in followup or no details | 21 | Phacoemulsification/trabeculectomy seemed to be their choice for cataract/glaucoma patients.
Bellucci, Luraschi, 1998 Europe | NRCT | To compare long-term glaucoma control in 1-site versus 2-site combined phacoemulsification/trabeculectomy. | 20 | NR | 75.5 | Acute IOP; Long-term IOP | 6 to 11 months | Minimal or no inclusion/exclusion details | 24 | IOP control was similar in both groups at 2 years postoperatively but patients in 1-site group required more glaucoma medications. However, this non-randomized study evaluated a small number of patients.
Berestka, Brown, 1997 United States | Cohort | To compare limbus-based versus fornix-based conjunctival flaps with 1-site phacoemulsification/trabeculectomy using MMC. | 52 | 0.00 | 76.0 | Long-term IOP; Complications | NR | No masking; Important/unknown baseline differences | 48 | This is a review of combined cases with higher incidence of PC rupture using limbus-based flaps. Otherwise, results appear similar but surgical procedure and length of followup were different between the groups.
Blondeau, Phelps, 1981 United States | RCT | To compare the efficacy and safety of trabeculectomy and thermosclerostomy for the treatment of open angle glaucoma. | 98 | 0.15 | 59.7 | Long-term IOP; Cataract; Complications; Postoperative visual acuity | 24 months or longer | No masking | 75 | Although trabeculectomy is slightly less effective than thermosclerostomy in lowering pressure, its relative freedom from complications make it a more desirable filtering operation.
Bloomberg, 1996 United States | Clinical series | To study the safety and effectiveness of a combined modified trabeculectomy and trabeculotomy with no stitch cataract surgery. | NR | NR | NR | Long-term IOP; Complications | 24 months or longer | N/A | N/A | Trabeculectomy/trabeculotomy with no stitch phacoemulsification was both safe and effective in this series of 100 patients.
Bobrow, 1998 United States | RCT | To assess long-term IOP control with cataract extraction combined with trabeculectomy versus cataract extraction alone. | 70 | 0.14 | 70.0 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 24 months or longer | No masking | 82 | Both ECCE/IOL and ECCE/IOL with trabeculectomy lower IOP chronically but the latter is more effective.
Borggrefe, Lieb, Grehn, 1999 Europe | RCT | To compare a 1-site versus a 2-site approach to phacoemulsification/trabeculectomy. | 50 | NR | 74.3 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | None | 64 | Both 1-site and 2-site techniques of combining trabeculectomy and phacoemulsification/IOL placement are safe and effective to lower IOP and improve VA.
Budenz, Pyfer, Singh et al., 1999 United States | Cohort | To estimate the effect of MMC and 5-FU on success of IOP control in phacoemulsification/trabeculectomy. | 78 | 0.37 | 74.3 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking | 58 | MMC was equal to no antifibrosis, except better than 5-FU in IOP postoperatively. African-Americans did worse postoperatively compared to others in this retrospective study.
Burratto, Ferrari, 1990 Europe | Clinical series | To assess IOP, visual acuity, and visual fields after ECCE/IOL for patients with cataract and glaucoma and prior filtering procedure. | 104 | NR | NR | Long-term IOP; Complications; Postoperative visual acuity | 6 to 11 months | N/A | N/A | ECCE/IOL does not appear to worsen the IOP control of previously existing filters with cataract status post filtering procedure without worsening of IOP.
Calissendorff, Hamberg-Nystrom, 1992 Europe | Clinical series | To assess long-term IOP control after ECCE/IOL in glaucomatous eyes. | 113 | NR | 77.0 | Long-term IOP | 24 months or longer | N/A | N/A | ECCE/IOL has a beneficial effect on IOP in glaucoma patients.
Caprioli, Park, Weitzman, 1996 United States | Cohort | To determine IOP lowering effects of combined phacoemulsification and superior trabeculectomy with trabeculectomy alone. | 80 | 0.04 | 74.8 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking | 83 | IOP control was better with trabeculectomy alone than with combined phacoemulsification procedure.
Caprioli, Park, Kwon et al., 1997 United States | Case control | To evaluate the effect of temporal clear corneal phacoemulsification on IOP in eyes that had prior trabeculectomy. | 80 | 0.08 | 71.8 | Long-term IOP; Complications; Postoperative visual acuity | 24 months or longer | N/A | N/A | Temporal clear corneal phacoemulsification in eyes with prior filtering blebs does not adversely effect IOP after one year of followup.
Carlson, Alward, Barad et al., 1997 United States | RCT | To evaluate the effectiveness of MMC during combined phacoemulsification/trabeculectomy with regard to IOP control and medication use postoperatively. | 29 | 0.03 | 72.6 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Important/unknown baseline differences | 79 | MMC in 1-site combined procedures produced consistently lower IOP in this small study with one-year of followup. Complications were similar in the MMC and placebo groups.
Chen, Weaver, Budenz et al., 1998 United States | Clinical Series | To examine the effect of cataract extraction on IOP in eyes with preexisting trabeculectomy. | 115 | 0.15 | 68.9 | Long-term IOP; Complications; Postoperative visualacuity | 12 to 23 months | N/A | N/A | Over 90% of patients undergoing either ECCE or PECE with existing filtering blebs were able to maintain IOP control with either no additional medicine, additional medicine, or bleb needling. It is not clear how this compares to a population of patients with filtering blebs who did not have cataracts removed.
Cheung, Wright, Murali et al., 1997 United States | Clinical series | To evaluate 1 to 3 years visual and IOP outcomes for trabeculectomy with MMC. | 157 | 0.01 | 67.8 | Acute IOP; Long-term IOP; Cataract; Complications | 12 to 23 months | N/A | N/A | In a predominantly white population, many of whom had cataract extraction or previous failed trabeculectomy, success rates of MMC trabeculectomy by life table analysis were 94% at 1 year, 92% at 2 years, and 89% at 3 years.
Chia, Goldberg, 1998 Australia | Cohort | To compare ECCE/ trabeculectomy with phacoemulsification/ trabeculectomy, 1-site. | 100 | NR | 75.7 | Long-term IOP; Complications | 12 to 23 months | No masking | 50 | ECCE combined procedures had more complications and produced less IOP-lowering than phacoemulsification, but the study used historical controls.
Cinotti, Fiore, Maltzman et al., 1998 United States | Clinical series | To assess the safety of performing ECCE/IOL in patients with glaucoma. | 160 | NR | 74.7 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | N/A | N/A | IOP decreased after ECCE and slowly returned to baseline at 2 years, and patients required less glaucoma medication.
Cohen, 1990 United States | Cohort | To compare IOP control with versus without 5-FU during combined ECCE/IOL and filtering surgery. | 44 | 0.14 | 74.3 | Acute IOP; Long-term IOP; Complications | 6 to 11 months | No masking; Differences in followup or no details | 61 | 5-FU group had no better postoperative IOP control than group without 5-FU.
Cohen, Greff, Novack et al., 1996 United States | RCT | To study the efficacy and safety of MMC in patients undergoing trabeculectomy and phacoemulsification. | 71 | 0.18 | 76.0 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | None | 69 | MMC use was associated with greater postoperative IOP control than placebo. However, more complications were observed with group receiving MMC.
Collaborative Normal-Tension Glaucoma Study Group, 1998a United States | RCT | To compare glaucomatous progression with versus without treatment to lower IOP in patients with normal tension glaucoma. | 140 | 0.05 | 65.9 | Cataract; Complications | 24 months or longer | No masking | 67 | Cataracts occurred more often in patients who had glaucoma surgery than in those not treated or treated medically.
Collaborative Normal-Tension Glaucoma Study Group, 1998b United States | RCT | To assess effectiveness of IOP reduction in treatment of normal tension glaucoma. | 145 | NR | NR | Cataract; Complications | 24 months or longer | No masking | 67 | Followup of previous study, included 5 more eyes in the treatment group, which are not characterized. More cataract in trabeculectomy patients.
Costa, Smith, Spaeth et al., 1993 United States | Case control | To determine the incidence and etiology of visual acuity loss within 3 months of trabeculectomy. | 84 | 0.12 | 68.0 | Long-term IOP; Cataract; Complications; Postoperative visual acuity | 3 to 5 months | N/A | N/A | Lens opacity was the main cause of early visual acuity loss after trabeculectomy.
Crandall, 1991 United States | Clinical series | To examine the outcomes and complications of combined phacoemulsification/ trabeculectomy. | 100 | 0.02 | 70.4 | Complications | 12 to 23 months | N/A | N/A | Phacoemulsification plus trabeculectomy may be satisfactory in patients with cataract and glaucoma.
Crestani, De Natale, Steindler, 1997 Europe | Cohort | To compare the use of a punch during combined procedures to force excision of a cornea-scleral block. | NR | NR | 65.0 | Long-term IOP; Postoperative visual acuity | NR | Minimal or no inclusion/exclusion details; Important/unknown baseline differences; Little or no surgical details; Differences in followup or no details | 3 | This small series of patients showed similar IOP results with punch as with “Cairns” technique.
Dastur, 1994 Bombay, India | NRCT | To evaluate the efficacy of early trabeculectomy in early chronic simple glaucoma. | 140 | NR | 59.7 | Long-term IOP; Cataract; Postoperative visual acuity | 24 months or longer | No masking; Important/unknown baseline differences | 44 | Early trabeculectomy for chronic simple glaucoma resulted in large reductions of IOP, reduced the size of optic disc cupping and decreased visual field loss.
Demailly, Kretz, 1992 Europe | RCT | To compare the effectiveness of Daunorubicin versus 5-FU on IOP control, visual acuity, and complications following trabeculectomy. | 27 | NR | 51.2 | Long-term IOP; Cataract; Complications | 6 to 11 months | No masking; Differences in followup or no details | 35 | Results were similar between the two drugs. However, the small sample size of the study limits the usefulness of the results.
Derick, Evans, Baker, 1998 United States | Cohort | To compare results of combined phacoemulsification/ trabeculectomy plus MMC versus trabeculectomy plus MMC. | 84 | 0.11 | 74.9 | Acute IOP; Long-term IOP; Cataract; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Important/unknown baseline differences | 63 | Success rate for combined phacoemulsification/ trabeculectomy approaches that of trabeculectomy alone.
Donoso, Rodriguez, 2000 Chile | Case control | To compare phacoemulsification after prior trabeculectomy to combined phacoemulsification and trabeculectomy. | 40 | NR | 76.5 | Long-term IOP; Complications | 12 to 23 months | N/A | N/A | IOP control was the same in combined phacoemulsification/ trabeculectomy as in sequential trabeculectomy and later phacoemulsification.
El-Sayyad, Helal, El-Maghraby et al., 1999 Saudi Arabia | RCT | To compare 1-site and 2-site combined phacoemulsification with foldable IOL and trabeculectomy. | 76 | NR | 65.5 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | NR | No masking | 61 | Two-site approach resulted in slightly better IOP, but required moving the microscope twice during surgery. However, the 2-site group was on slightly more medication at one year.
El-Sayyad, Helal, Khalil et al., 1999 Saudi Arabia | Case control | To compare two-stage trabeculectomy/ phacoemulsification to one-stage phacoemulsification/ trabeculectomy. | 106 | 0.24 | 50.1 | Long-term IOP; Complications; Postoperative visual acuity | NR | N/A | N/A | One-stage and two-stage phacoemulsification/ trabeculectomy gave similar IOP control.
Gandolfi, Vecchi, 1997 Europe | RCT | To compare long-term IOP control in phacoemulsification/ trabeculectomy with 5-FU compared to without 5-FU. | 24 | NR | 63.0 | Long-term IOP; Complications | 12 to 23 months | Baseline info poor; Important/unknown baseline differences | 62 | Using the two highest measurements of IOP by diurnal testing, adding 5-FU injections postoperatively improved the success of 2-site combined procedures in this small RCT with no obvious increase in adverse events.
Gayton, Van der Karr, Sanders, 1996 United States | Cohort | To compare in a retrospective study two different incisions for combined procedure. | 115 | NR | 75.5 | Long-term IOP | 12 to 23 months | Baseline info poor; No masking; Important/unknown baseline differences | 31 | No large difference noted between 2-site phacoemulsification/ trabeculectomy surgeries.
Gayton, Van der Karr, Sanders, 1999 United States | RCT | To study the effect of cataract surgery with endoscopic laser cycloablation versus cataract surgery combined with filtering surgery in inflammation. | 58 | 0.40 | NR | Long-term IOP; Complications | NR | No masking; Important/unknown baseline differences | 50 | Trabeculectomy consistently resulted in greater success on fewer medications than endoscopic laser, but hyphema and immediate postoperative inflammation were greater in the trabeculectomy group. Outliers may have influenced the results.
Gianoli, Schnyder, Bovey et al., 1999 Europe | RCT | To compare the outcome of two combined procedures: phacoemulsification/deep sclerectomy and phacoemulsification/ trabeculectomy. | 60 | NR | 80.1 | Long-term IOP; Complications; Postoperative visual acuity0 | 12 to 23 months | No masking; Differences in followup or no details | 59 | IOP lowering was similar in phacoemulsification/ trabeculectomy and phacoemulsification/ deep sclerectomy, with fewer short-term complications in the latter.
Gimbel, Meyer, DeBroff et al., 1995 Canada | RCT | To compare IOP control with combined phacoemulsification and trabeculotomy ab externo versus phacoemulsification alone. | 106 | NR | 76.5 | Acute IOP; Long-term IOP; Complications | 12 to 23 months | No masking | 63 | Combined phacoemulsification and trabeculotomy ab externo is an option to lower IOP and decrease the use of glaucoma medications in patients with POAG and cataracts.
Gunning, Greve, 1991 Europe | Clinical series | To determine the results of one technique of cataract extraction and IOL implantation in patients with versus without glaucoma. | 102 | NR | 75.2 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | N/A | N/A | Cataract extraction has a beneficial effect on IOP in glaucoma.
Hayashi, Hayashi, Nakao et al., 2000 Asia (Japan) | Cohort | To assess angle and IOP changes in ACG, OAG and non- glaucomatous individuals undergoing phacoemulsification. | 224 | NR | 73.0 | Long-term IOP | 12 to 23 months | None | 50 | IOP decreased about 20% after clear cornea phacoemulsification in individuals with ACG and OAG. Also, the width and depth of the AC angle in eyes with ACG increased significantly after phacoemulsification.
Hennis, Stewart, 1991 United States | RCT | To evaluate the safety and efficacy of a 14-day course of daily 5-FU injections following combined trabeculectomy. | 32 | 0.77 | 71.7 | Long-term IOP; Complications; Postoperative visual acuity | 3 to 5 months | None | 50 | This small, underpowered study, did not detect any harm or benefit to 5-FU use in combined ECCE/ trabeculectomy.
Honjo, Tanihara, Negi et al., 1996 Japan | Cohort | To compare different approaches combining trabeculotomy and cataract surgery. | 47 | NR | 71.4 | Long-term IOP; Complications | NR | Minimal or no Inclusion/exclusion details; Baseline info poor; Important/unknown Baseline differences | 13 | Trabeculotomy lowered pressure when combined with cataract extraction, but many still had IOP > 21.
Hugkulstone, Sadiq, Rubasingham, 1997 Europe | RCT | To assess IOP control with standard versus heparin-coated IOLs following combined cataract and glaucoma surgery. | 19 | NR | 80.1 | Long-term IOP; Complications | 24 months or longer | Minimal or no inclusion/exclusion details; No masking | 56 | Use of heparin-coated IOL does not adversely effect IOP control after combined cataract and drainage surgery and was associated with a greater fall in IOP at 2 years.
Hurvitz, 1993 United States | Cohort | To report long-term results of glaucoma triple procedure phacoemulsification/ trabeculectomy, IOL with or without 5-FU and ECCE/ trabeculectomy without 5-FU. | NR | NR | 76.3 | Long term IOP; Complications | 12 to 23 months | No masking; Important/unknown baseline differences | 33 | The decrease in IOP was marginally greater in the group receiving 5-FU than in the group not receiving 5-FU. However, possible selection biases and the learning curve of the surgeon limit the conclusion.
Jayamanne, Kostakis, Phelan, 1997 Europe | Clinical series | To examine glaucoma control in patients undergoing combined small incision cataract surgery (phacoemulsification) and trabeculectomy. | 100 | NR | NR | Long-term IOP; Complications | 6 to 11 months | N/A | N/A | Phacoemulsification/ trabeculectomy lowered IOP in most patients followed for 6–12 months.
Jerndal, Lundstrom, 1980 Europe | Clinical series | To report outcomes in a large (early) series of trabeculectomies. | 281 | NR | 66.0 | Long-term IOP; Cataract | 24 months or longer | N/A | N/A | Trabeculectomy is a viable surgical technique to lower IOP.
Karlen, Sanchez, Schnyder et al., 1999 Europe | Clinical series | To study prospectively, the success rate and complications of deep sclerectomy with collagen implant. | 100 | 0.00 | 71.0 | Long-term IOP; Cataract; Complications | 12 to 23 months | N/A | N/A | Deep sclerostomy with collagen implant appears to provide reasonable control of IOP at medium term followup, with few immediate postoperative complications.
Kendrick, Kollarits, Khan, 1996 United States | Cohort | To determine whether ab interno laser thermal sclerostomy combined with cataract surgery would be as effective as trabeculectomy combined with cataract surgery. | 70 | NR | 78.5 | Long-term IOP | NR | Minimal or no inclusion/exclusion details; No masking; Important/unknown baseline differences | 20 | Phacoemulsification plus Holmium ab interno sclerostomy is as effective as phacoemulsification plus trabeculectomy.
Kim, Jung, Hwang, 1998 Korea | RCT | To compare the effects of 3 types of combined phacoemulsification/ trabeculectomy. | 28 | 0.00 | 67.4 | Long-term IOP; Postoperative visual acuity | NR | No masking; Important/unknown baseline differences | 46 | Three different techniques of combined cataract and glaucoma surgery all lowered IOP at 6 months.
Kitazawa, Suemori-Matsushita, Yamamoto et al., 1993 Japan | RCT | To determine the optimum dose of intraoperative MMC with trabeculectomy. | 22 | NR | 55.4 | Long-term IOP; Cataract; Complications | 6 to 11 months | No masking | 73 | High dose MMC yielded better control of IOP than low dose MMC but was associated with increased hypotony and cataract progression.
Kooner, Dulaney, Zimmerman, 1988 United States | Clinical series | To assess IOP after ECCE/IOL in glaucoma patients. | 103 | NR | 75.3 | Long-term IOP; Complications | NR | N/A | N/A | ECCE/IOL could be performed in this group of glaucoma patients without worsening of IOP control.
Kosmin, Wishart, Ridges, 1997 Europe | Cohort | To compare glaucoma control in phacoemulsification/ trabeculectomy with silicone IOL and small incision versus PMMA-IOL and large incision. | 60 | NR | 75.5 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking | 60 | No large difference was seen between large incision, 1-site combined phacoemulsification/ trabeculectomy using more stitches and smaller incision 1-site combined.
Kosmin, Wishart, Ridges, 1998 Europe | Cohort | To compare long-term IOP control after ECCE and trabeculectomy versus phacoemulsification and trabeculectomy. | 63 | NR | 78.5 | Long-term IOP | 24 months or longer | Minimal or no inclusion/exclusion details; No masking | 50 | Phacoemulsification/ trabeculectomy led to a greater likelihood of IOP control on no medications using survival analysis. However, total IOP decrease was slightly greater in the ECCE/ trabeculectomy group.
Krupin, Feitl, Bishop, 1989 United States | RCT | To measure short-term IOP control after cataract surgery alone or combined with posterior lip sclerectomy. | 68 | 0.31 | 75.2 | Acute IOP; Long-term IOP; Complications | 24 hours or less | No masking; Important/unknown baseline differences | 54 | Many glaucoma patients undergoing cataract surgery will have a large immediate IOP spike. If combined surgery is performed, fewer do.
Lamping, Bellows, Hutchinson et al., 1986 United States | Clinical Series | To review the outcomes of filtration surgeries performed over a 14 year period. | 252 | NR | NR | Long-term IOP; Cataract; Complications | 24 months or longer | N/A | N/A | Cataract surgery was required in 30% of those undergoing glaucoma procedures at median 5 years. More eyes experiencing postoperative hypotony requiring choroidal drainage required cataract extraction.
Lemon, Shin, Kim et al., 1998 United States | RCT | To study the safety and efficacy of limbus-based versus fornix-based incisions in combined phacoemulsification/ trabeculectomy with MMC. | 69 | 0.63 | 74.0 | Long-term IOP; Complications | NR | None | 66 | No differences in postoperative IOP control or visual outcome were observed between groups receiving a limbus-based versus fornix-based conjunctival flap, with the use of MMC. Hypotony with a wound leak was more common in the limbus-based group.
Lewis, Phelps, 1984 United States | RCT | To compare trabeculectomy and thermosclerostomy in terms of long-term (5 year) effect on IOP and safety. | 71 | NR | 59.3 | Long-term IOP; Cataract; Complications | 24 months or longer | No masking | 76 | When compared with thermosclerostomy, trabeculectomy was significantly more likely to result in IOP control without further surgery or medications, and had significantly fewer complications.
Liu, Su, Chou et al., 2000 Taiwan | Case control | To evaluate the efficacy and safety of intraoperative MMC in combined phacoemulsification/ trabeculectomy. | 40 | NR | 69.0 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | N/A | 63 | Results of this small, retrospective study indicate that use of intraoperative MMC in combined phacoemulsification/ trabeculectomy resulted in greater success of filter and fewer complications than in phacoemulsification/ trabeculectomy alone.
Lyle, Jin, 1991 United States | Cohort | To assess the safety and efficacy of a 3mm incision phacoemulsification/ trabeculectomy, a 6mm incision phacoemulsification, and a 6mm incision phacoemulsification/ IOL/trabeculectomy. | 216 | NR | 75.5 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Differences in followup or no details | 64 | No significant difference between 3mm and 6mm incision groups in IOP control, but 3mm group had fewer complications and had better early postoperative visual acuity.
Mamalis, Lohner, Rand et al., 1996 United States | Clinical series | To evaluate glaucoma control and complications in patients undergoing combined phacoemulsification/ trabeculectomy. | 212 | NR | 73.0 | Long-term IOP; Complications | 24 months or longer | N/A | N/A | Combined 1-site phacoemulsification/ trabeculectomy on average lowered IOP and improved vision.
Manoj, Chako, Khan, 2000 Europe | Cohort | To compare IOP control between ECCE and phacoemulsification performed after prior trabeculectomy | 55 | NR | 77.2 | Long-term IOP | 24 months or longer | No masking; Important/unknown baseline differences | 33 | Phacoemulsification controlled IOP better than ECCE following prior trabeculectomy in patients with POAG. Phacoemulsification patients required no medications to control postoperative IOP. However, this is a small retrospective study.
McCartney, Memmen, Stark et al., 1988 United States | Clinical series | To assess efficacy and safety of combined trabeculectomy and cataract extraction/ IOL | 108 | NR | 73.0 | Long-term IOP; Complications; Postoperative visual acuity | NR | N/A | N/A | Good vision results and IOP results were observed with ECCE/IOL plus trabeculectomy.
McGuigan, Gottsch, Stark et al., 1986 United States | Cohort | To compare visual results and complications of ECCE/IOL in those with versus without glaucoma. | 90 | NR | 70.8 | Acute IOP; Cataract; Complications; Postoperative visual acuity | 12 to 23 months | Minimal or no inclusion/exclusion details; No masking | 40 | Cataract surgery did not decrease need for medication in glaucoma patients. Eyes with glaucoma had more IOP spikes in early period.
McKinzie, Boggs, 1989 United States | Cohort | To determine whether Miochol or Miostat is more effective in controlling IOP after cataract surgery. | 16 | NR | NR | Acute IOP | 24 hours or less | Minimal or no inclusion/exclusion details; No masking; Important/unknown baseline differences | 30 | Miostat was better than Miochol at controlling acute IOP after cataract surgery.
Montgomery, Gills, 1980 United States | Clinical series | To assess results of combined ECCE/IOL and cyclodialysis. | 238 | NR | NR | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | N/A | N/A | ECCE/IOL/Cyclo-dialysis is a good operation for cataract and glaucoma.
Murchison, Shields, 1989 United States | Cohort | To compare 3 approaches to coexisting glaucoma and cataract: 1) combined guarded filtering procedure; 2) 2-stage filtering surgery then cataract extraction; 3) cataract surgery alone. | 78 | NR | 71.0 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Important/unknown baseline differences | 44 | Fewer early postoperative IOP increases observed with combined procedures than with cataract surgery alone but fewer complications with latter; similar final IOP in all 3 groups.
Murchison, Shields, 1990 United States | Cohort | To compare limbal-based versus fornix-based conjunctival flaps in combined ECCE and glaucoma filtering procedure. | 47 | 0.17 | 73.5 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking | 67 | Limbal-based surgery had better early postoperative IOP control than fornix-based ECCE/trabeculectomy but similar long-term IOP control and visual acuity.
Naveh, Kottass, Glovinsky et al., 1990 Israel | Cohort | To compare long-term IOP control with trabeculectomy plus cataract extraction (ECCE) versus trabeculectomy alone. | 78 | NR | 71.0 | Long-term IOP | 12 to 23 months | No masking; Important/unknown baseline differences | 48 | Postoperative IOP significantly lower after trabeculectomy than after combined trabeculectomy plus ECCE.
Neumann, Zalish, Oliver, 1988 Israel | Cohort | To assess the effect of IOL implantation on combined ECCE with trabeculectomy. | 46 | NR | 73.3 | Acute IOP; Long-term IOP; Complications | 6 to 11 months | No masking; Important/unknown baseline differences; Differences in followup or no details | 34 | IOP implantation did not have a detrimental effect on postoperative IOP or visual acuity, but was associated with increased minor anterior chamber reactions.
Nielsen, 1997 Europe | NRCT | To compare two different approaches to making a trabeculectomy incision in 1-site phacoemulsification/ trabeculectomy. | 26 | NR | NR | Long-term IOP; Complications | 12 to 23 months | Baseline info poor; No masking; Important/unknown baseline differences | 29 | More hyphema and vitreous hemorrhage with a more posterior wound. IOPs were similar. Blebs appeared more “functional” with posterior wound.
Noben, Linsen, Zeyen, 1998 Europe | Case control | To compare the IOP control of trabeculectomy versus phacoemulsification/ trabeculectomy combined. | NR | NR | 72.5 | Long-term IOP; Complications | 12 to 23 months | N/A | N/A | In this retrospective review, IOP was better controlled after trabeculectomy than after combined surgery.
O'Grady, Juzych, Shin et al., 1993 United States | RCT | To study whether 5-FU increases the success of combined primary trabeculectomy and phacoemulsification surgery. | NR | NR | 72.8 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Minimal or no inclusion/exclusion details | 45 | Postoperative management with low dose 5-FU did not improve postoperative outcomes in patients undergoing combined trabeculectomy and phacoemulsification compared to controls and increased the rate of SPK substantially
Onali, Raitta, 1991 Europe | Clinical series | To show short-term and long-term effects of ECCE/IOL on IOP and glaucoma control in simple glaucoma and capsular glaucoma. | 103 | NR | 77.0 | Long-term IOP; Complications | 24 months or longer | N/A | N/A | ECCE with IOL is indicated for OAG eyes with preoperatively controlled IOP although 30% of cases had a rise in IOP in the 1st to 2nd postoperative day.
Park, Weitzman, Caprioli, 1997 United States | Cohort | To compare glaucoma control in patients receiving phacoemulsification/ trabeculectomy with 5-FU compared to patients receiving trabeculectomy alone with 5-FU. | 80 | 0.04 | 74.8 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking | 63 | Two-site combined procedure lowered IOP, but IOPs were not as well controlled when compared with a group undergoing primary trabeculectomy.
Perasalo, 1997 Europe | Clinical series | To examine IOP control in patients with glaucoma undergoing small incision phacoemulsification with IOP implant. | 226 | NR | 81.6 | Long-term IOP; Complications | NR | N/A | N/A | If glaucoma is fairly well controlled, phacoemulsification alone can result in satisfactory IOP control in eyes with capsular glaucoma and POAG.
Robin, 1993 United States | RCT | To compare acute IOP after combined glaucoma and cataract surgery with versus without apraclonidine. | 109 | 0.07 | 75.0 | Acute IOP; Long-term IOP | 1 week to 29 days | None | 76 | IOP can be high one day after ECCE/IOL/ trabeculectomy but this is less frequent if apraclonidine is used preoperatively.
Robin, Ramakrishnan, Krishnadas et al., 1997 India | RCT | To establish the long-term, dose-response relationship between concentration and duration of MMC to postoperative IOP and complications. | 300 | NR | 51.7 | Long-term IOP; Cataract; Complications | NR | Important/unknown baseline differences | 78 | IOP control tended to increase with higher concentration or longer duration of MMC, but with an increased incidence of cataract.
Rossetti, Bucci, Miglior et al., 1997 Europe | RCT | To compare long-term IOP control between 1-site and 2-site phacoemulsification/ trabeculectomy. | 50 | NR | NR | Long-term IOP | NR | Minimal or no inclusion/exclusion details; Important/unknown baseline differences; Little or no surgical details; Differences in followup or no details | 11 | One-site trabeculectomy appeared to have slightly worse IOP control than 2-site (with clear cornea). However baseline demographics and ancillary treatments were not reported.
Sanders, Cantor, Dobler et al., 1999 United States | RCT | To compare outcome of trabeculectomy using either 0.2 mg. or 0.4 mg. MMC. | 50 | 0.12 | 72.5 | Acute IOP; Long-term IOP; Cataract; Complications; Postoperative visual acuity | 6 to 11 months | None | 88 | Low dose (0.2) as effective as high dose (0.4) MMC in eyes with previous surgery, with slightly fewer complications.
Savage, Thomas, Belcher et al., 1985 United States | Cohort | To assess results of ECCE with or without IOL in patients with and without glaucoma. | 296 | NR | NR | Long-term IOP; Complications | NR | No masking; Important/unknown baseline differences; Differences in followup or no details | 29 | Implantation of IOL did not influence postoperative IOP. Open angle glaucoma developed in 1.4% of normal eyes after ECCE/IOL.
Shin, Kim, Ren et al., 1998 United States | RCT | To report the effect of intraoperative MMC on the incidence of PCO requiring YAG-capsulotomy in combined trabeculectomy/ phacoemulsification. | 174 | 0.50 | 74.5 | Complications | 24 months or longer | None | 78 | Intraoperative application of MMC decreases the risk of developing PCO requiring YAG. No information was provided on complications or postoperative IOP.
Shin, Ren, Juzych et al., 1998 United States | RCT | To compare filtration success using MMC in primary glaucoma triple procedure versus none. | 197 | 0.51 | 74.3 | | 24 months or longer | None | 78 | MMC in combined cases appears to increase the likelihood of “success” in blacks, individuals with high preoperative IOP, and those on multiple medications.
Shin, Kim, Sheth et al., 1998 United States | RCT | To compare glaucoma control using MMC for secondary glaucoma triple procedures to using no antimetabolite. | 49 | 0.65 | 68.3 | | 24 months or longer | Minimal or no inclusion/exclusion details | 53 | MMC appeared to increase the “success rate” over no antifibrosis in secondary glaucoma triple procedures.
Shingleton, Jacobson, Kuperwaser, 1995 United States | Cohort | To compare IOP reduction in patients receiving combined ECCE/trabeculectomy versus combined phacoemulsification/ trabeculectomy. | 72 | 0.00 | 76.5 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Important/unknown baseline differences | 46 | Phacoemulsification combined with trabeculectomy resulted in slightly better postoperative IOP control compared to ECCE/ trabeculectomy.
Shingleton, Chaudhry, O'Donoghue et al., 1999 United States | NRCT | To compare outcome of limbus versus fornix-flap phacoemulsification/ trabeculectomy. | 88 | 0.00 | 75.4 | Long-term IOP; Complications; Postoperative visual acuity | NR | Minimal or no inclusion/exclusion details | 63 | Similar IOP control and complications with fornix and limbus-based phacoemulsification/ trabeculectomy.
Shingleton, Gamell, O'Donoghue et al., 1999 United States | Cohort | To study the effect of corneal phacoemulsification on “glaucoma” (IOP). | 310 | NR | 73.3 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | NR | No masking; Important/unknown baseline differences | 59 | Corneal phacoemulsification lowers IOP (but no decrease in medications was seen preoperatively).
Spaeth, 1980 United States | RCT | To compare effectiveness and safety of trabeculectomy and full thickness procedure. | 30 | NR | NR | Long-term IOP; Cataract; Complications | 24 months or longer | Minimal or no inclusion/ exclusion details; No masking; Important/unknown baseline differences | 22 | Trabeculectomy and thermal sclerostomy have similar effects and complications.
Stewart, Crinkley, Carlson, 1994a United States | Case control | To study IOP control and complications in phacoemulsification with trabeculectomy using a limbus-based verus fornix-based flap. | 31 | 0.48 | 74.0 | Long-term IOP; Complications; Postoperative visual acuity | NR | N/A | N/A | Both approaches yielded similar outcomes postoperatively. The limbus-based approach had slightly more complications.
Stewart, Crinkley, Carlson, 1994b United States | Case control | To compare postoperative IOP control and visual acuity in eyes undergoing combined phacoemulsification/ trabeculectomy to eyes undergoing ECCE/ trabeculectomy. | NR | NR | 72.2 | Long-term IOP; Complications; Postoperative visual acuity | 6 to 11 months | N/A | 36 | Phacoemulsification plus trabeculectomy is as effective as ECCE plus trabeculectomy in controlling postoperative IOP in this small study.
Storr-Paulsen, Pedersen, Laugesen, 1998 Europe | RCT | To compare phacoemulsification and trabeculectomy to phacoemulsification for coexisting cataract and glaucoma. | 20 | NR | 80.0 | Acute IOP; Long-term IOP; Complications; Postoperative visual acuity | 6 to 11 months | No masking | 72 | IOP fell with phacoemulsification alone, but more with combined phacoemulsification/ trabeculectomy. Fewer medications required after phacoemulsification/ trabeculectomy.
Tanihara, Negi, Akimoto et al., 1993 Japan | Clinical series | To describe a modified trabeculectomy and report outcomes of this surgical technique. | 439 | NR | 50.8 | Cataract; Complications | 24 months or longer | N/A | N/A | Trabeculotomy seldom results in medication- free control of IOP, even in a group with favorable surgical prognosis.
Tezel, Kolker, Kass et al., 1997a United States | Cohort | To compare limbus versus fornix-based flaps in combined phacoemulsification/ trabeculectomy. | 215 | 0.11 | 75.0 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Minimal or no inclusion/exclusion details | 40 | Limbus-based and fornix-based conjunctival flaps appear to be comparable after a combined phacoemulsification/ trabeculectomy with MMC.
Tezel, Kolker, Kass et al., 1997b United States | Cohort | To compare long-term IOP control and visual outcomes between combined trabeculectomy with ECCE versus combined trabeculectomy with phacoemulsification. | 397 | 0.11 | 76.4 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Minimal or no inclusion/exclusion details | 48 | The combination of combined phacoemulsification, releasable scleral flap sutures, and foldable IOL is the best regarding IOP control and visual acuity, compared to combined with ECCE and a rigid IOL.
Tornqvist, Drolsum, 1991 Europe | Clinical series | To study rate of visual field progression up to 10 years after trabeculectomy. | 277 | NR | 70.0 | Long-term IOP; Cataract; Complications | NR | N/A | N/A | Only 42% of eyes failed to demonstrate visual field progression 10 years after trabeculectomy. A major cause of vision loss and visual field progression is cataract.
Tuulonen, Niva, Alanko, 1987 Europe | NRCT | To determine the long term efficacy of laser trabeculoplasty as primary therapy in simple and capsular glaucoma compared to initial medical treatment. | 64 | NR | 63.5 | Long-term IOP;Cataract | 24 months or longer | No masking | 56 | IOP and optic disk outcomes are significantly better for early glaucoma patients treated initially with ALT than for those treated initially with medications without the option of receiving ALT.
Vu, Shields, 1988 United States | NRCT | To compare early postoperative IOP in glaucoma patients after ECCE/IOL versus ICCE. | 50 | 0.08 | 69.7 | Acute IOP | 1 to 2 months | Minimal or no inclusion/exclusion details; No masking; important/unknown baseline differences | 36 | IOP elevation common after cataract (ECCE or ICCE) surgery in glaucoma patients
Vyas, Bacon, Percival, 1998 Europe | NRCT | To compare IOP results after 3.5mm versus 5.2mm incision phacoemulsification/trabeculectomy. | 50 | 0.00 | 73.7 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Important/unknown baseline differences | 35 | No differences were observed between the 3.5mm and 5.2mm incision groups. However fewer complications were seen with the larger incision.
Wand, 1996 United States | Cohort | To compare the difference in IOP control using a 6.0mm incision to that using a 3.2mm incision during a 1-site combined procedure with MMC. | 57 | 0.14 | 76.0 | Long-term IOP; Complications; Postoperative visual acuity | 6 to 11 months | No masking; Differences in followup or no details | 57 | Similar outcomes with combined phacoemulsification/trabeculectomy 1-site procedure with MMC using a 6.0mm incision and a 3.2mm incision. The laser incision group was operated in one year before the smaller incision group.
Watson, Jakeman, Ozturk et al., 1990 Europe | Clinical serie | To assess long-term outcomes of trabeculectomy. | 150 | NR | NR | Long-term IOP; Cataract | 24 months or longer | N/A | N/A | Excellent long-term IOP control with few complications. Cataracts developed or progressed in 14.3% of cases, but no control group presented for comparison.
Wedrich, Menapace, Hirsch et al., 1996 Europe | Cohort | To compare the results of combined ECCE and trabeculectomy to combined phacoemulsification/trabeculectomy throught a small incision. | NR | NR | 76.9 | Long-term IOP; Complications | 24 months or longer | Minimal or no inclusion/exclusion details; No masking | 43 | Phacoemulsification/trabeculectomy yielded better results in this study. However, interpretation of the findings is limited by the methodology.
West, Burke, Cunliffe et al., 1992 Europe | RCT | To compare acetazolamide and acetylcholine for reducing acute postoperative IOP rises after cataract extraction. | 36 | NR | 79.3 | Acute IOP | 24 hours or less | None | 69 | Combined acetazolamide and acetylcholine was most effective in controlling acute postoperative IOP.
Wilson, 1989 St. Lucia | RCT | To compare posterior lip sclerectomy versus trabeculectomy for primary open angle glaucoma | 80 | 1.00 | 63.8 | Long-term IOP; Cataract; Complications | 24 months or longer | No masking | 74 | Postoperative IOP was lower and bleb more cystic after posterior lip sclerectomy than trabeculectomy with no signigicant difference in visual acuity but higher rate of complications.
Wishart, Austin, 1993 Europe | Cohort | To compare the effectiveness of phacoemulsification and trabeculectomy to ECCE and trabeculectomy. | 68 | NR | 78.5 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | No masking; Differences in followup or no details | 54 | Phacoemulsification with trabeculectomy resulted in better IOP control with many fewer complications than did ECCE with trabeculectomy.
Wong, Ruderman, Krupin et al., 1994 United States | RCT | To study the safety and effectiveness of 5-FU on intraocular pressure in eyes with open angle glaucoma following combined trabeculectomy and ECCE. | 44 | 0.10 | 75.0 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | Little or no surgical details | 62 | No differences were observed postoperatively in eyes receiving 5-FU compared to control eyes for IOP, number of medications, or visual acuity. Use of 5-FU was associated with SPK.
Wyse, Meyer, Ruderman et al., 1998 United States Reference No.: 97 | RCT | To compare glaucoma control in 1-site versus 2-site combined phacoemulsification/trabeculectomy. | 33 | NR | 75.0 | Long-term IOP | 12 to 23 months | No masking | 60 | Results of this small sample were similar in both groups with respect to IOP. 1-site group required slightly more glaucoma medications at last followup.
Yalvac, Airaksinen, Tuulonen, 1997 Europe | Cohort | To determine the postoperative IOP in patients with glaucoma who underwent phacoemulsifictaion with and without trabeculectomy. | 56 | NR | 79.0 | Long-term IOP; Complications; Postoperative visual acuity | NR | Important/unknown baseline differences | 46 | Cataract surgery either phacoemulsification alone or combined with trabeculectomy induces significant reductions of IOP in patients with glaucoma.
Yang, Moster, Azuara-Blanco et al., 1997 United States | Clinical series | To evaluate glaucoma control in patients undergoing combined phacoemulsification/trabeculectomy with MMC. | 182 | 0.12 | 74.5 | Long-term IOP; Complications; Postoperative visual acuity | 12 to 23 months | N/A | N/A | IOP decreased significantly after combined phacoemulsification/trabeculectomy with MMC. However, visual outcomes were worse than in a previously reported series of combined procedures.
Yu, Chong, Caesar et al., 1996 Europe | Cohort | To compare long-term IOP control in patients undergoing a glaucoma triple procedure (ECCE, IOL implantation, trabeculectomy) to patients receiving trabeculectomy alone. | 45 | 0.00 | 77.9 | Long-term IOP; Complications; Postoperatvie visual acuity | 12 to 23 months | No masking | 65 | Simialr long-term results were obwerved for the group receiving a combined procedure and the group receiving trabeculectomy alone. Although patients were "low risk", more postoperative complications were observed in the group receiving the combined procedure.

Evidence Table 2. Summary of interventions reported in literature on treatment of coexisting cataract and glaucoma

Study Information (Author, Year; Location) | Study Group | Treatments | Trabeculectomy (Incision, Location) | Cataract (Procedure, Incision) | Trabeculoplasty (Wavelength, Angle, Power) | Endoscopic Laser (Angle Treated, Laser Power) | Mitomycin-C (Concentration, Duration) | Intraoperative 5-Fluorouracil (Concentration, Duration) | Postoperative 5-Fluorouracil (Dose, # of Injections)
Advanced Glaucoma Intervention Study, The (AGIS), 1998 United States | 1 | Trabeculoplasty | | | WaveLength: Can't Tell Angle: 360° Power: Can't Tell
| 2 | Trabeculectomy | Can't Tell
| 3 | Trabeculoplasty | | | WaveLength: Can't Tell Angle: 360° Power: Can't Tell
| 4 | Trabeculectomy | Can't Tell
Anand, Menage, Bailey, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 2-site
| 3 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Anders, Pham, Holschbach et al., 1997 Europe | 1 | Cataract extraction Radial incision | Fornix | Phaco. Scleral 1-site
| 2 | Cataract extraction | | Phaco. Scleral
Arnold, 1996 United States | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Asamoto, Yablonski, 1993 United States | 1 | Trabeculectomy Air | Can't Tell
| 2 | Trabeculectomy BSS | Can't Tell
| 3 | Trabeculectomy Healon | Can't Tell
| 4 | Trabeculectomy | Can't Tell
Bellucci, Perfetti, Babighian et al., 1997 Europe | 1 | Trabeculectomy | Limbus
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Bellucci, Luraschi, 1998 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Clear cornea 2-site
Berestka, Brown, 1997 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | Can't Tell Can't Tell | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | Can't Tell Can't Tell | | Can't Tell Can't Tell
Blondeau, Phelps, 1981 United States | 1 | Trabeculectomy | Fornix
| 2 | Thermosclerostomy
Bloomberg, 1996 United States | 1 | Trabeculectomy Cataract extraction Trabeculectomy | Limbus | Phaco. 1-site
Bobrow, 1998 United States | 1 | Trabeculectomy Cataract extraction | Limbus | ECCE Scleral
| 2 | Cataract extraction | | ECCE Scleral
Borggrefe, Lieb, Grehn, 1999 Europe | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Scleral | | | | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 2-site | | | | | Can't Tell Can't Tell
Budenz, Pyfer, Singh et al., 1999 United States | 1 | Trabeculectomy Cataract extraction Other medications | Can't Tell | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Can't Tell | Phaco. 1-site | | | | | 5mg Can't Tell
| 3 | Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Can't Tell | Phaco. 1-site | | | Can't Tell Can't Tell | | 5mg Can't Tell
Burratto, Ferrari, 1990 Europe | 1 | Cataract extraction | | Phaco. Scleral
Calissendorff, Hamberg-Nystrom, 1992 Europe | 1 | Cataract extraction | | ECCE Scleral
Caprioli, Park, Weitzman, 1996 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 2-site | | | | | 5mg Can't Tell
| 2 | Trabeculectomy Antifibrosis agents | Limbus | No CE | | | | | 5mg Can't Tell
Caprioli, Park, Kwon et al., 1997 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Limbus | Phaco. Clear cornea | | | | | 5mg Can't Tell
| 2 | Trabeculectomy Antifibrosis agents Other medications | Limbus | No CE | | | | | 5mg Can't Tell
Carlson, Alward, Barad et al., 1997 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.5mg/ml 3–3.9 minutes
| 2 | Trabeculectomy Cataract extraction | Limbus | Phaco. 1-site
Chen, Weaver, Budenz et al., 1998 United States | 1 | Cataract extraction Antifibrosis agents | | Scleral Clear cornea | | | | | Can't Tell Can't Tell
Cheung, Wright, Murali et al., 1997 United States | 1 | Trabeculectomy Antifibrosis agents | Fornix | | | | Can't Tell Can't Tell | | Can't Tell Can't Tell
Chia, Goldberg, 1998 Australia | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | ECCE 1-site | | | | | 5mg Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | | | 5mg Can't Tell
Cinotti, Fiore, Maltzman et al., 1998 United States | 1 | Cataract extraction | | ECCE Scleral
Cohen, 1990 United States | 1 | Trabeculectomy Cataract extraction | Fornix | Can't Tell Scleral
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Can't Tell Scleral | | | | | 5mg Can't Tell
Cohen, Greff, Novack et al., 1996 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | 0.5mg/ml 2–2.9 minutes
| 2 | Trabeculectomy Cataract extraction Balanced salt placebo | Fornix | Phaco. Scleral 1-site
Collaborative Normal-Tension Glaucoma Study Group, 1998a United States | 1 | Trabeculoplasty Trabeculectomy Cataract extraction Other medications | Can't Tell | Can't Tell Can't Tell | WaveLength: Can't Tell Angle: Can't Tell Power: Can't Tell | | Can't Tell Can't Tell | Can't Tell Can't Tell | Can't Tell Can't Tell
| 2 | Cataract extraction | | Can't Tell Can't Tell
Collaborative Normal-Tension Glaucoma Study Group, 1998b United States | 1 | Trabeculoplasty Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Can't Tell | Can't Tell Can't Tell | WaveLength: Can't Tell Angle: Can't Tell Power: Can't Tell | | Can't Tell Can't Tell | Can't Tell Can't Tell | Can't Tell Can't Tell
| 2 | Cataract extraction | | Can't Tell Can't Tell
Costa, Smith, Spaeth et al., 1993 United States | 1 | Trabeculectomy Antifibrosis agents | Can't Tell | | | | | Can't Tell Can't Tell | Can't Tell Can't Tell
| 2 | Trabeculectomy Antifibrosis agents | Can't Tell | | | | | Can't Tell Can't Tell | Can't Tell Can't Tell
Crandall, 1991 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | | | 5mg Can't Tell
Crestani, De Natale, Steindler, 1997 Europe | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | Phaco. 1-site | | | | | Can't Tell 1
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | Phaco. 1-site | | | | | Can't Tell 5
Dastur, 1994 Bombay, India | 1 | Trabeculectomy | Limbus
| 2 | Other medications
Demailly, Kretz, 1992 Europe Reference No.: | 1 | Trabeculectomy Antifibrosis agents | Limbus | | | | | | 5mg 10
| 2 | Trabeculectomy Antifibrosis agents | Limbus
Derick, Evans, Baker, 1998 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Scleral | | | 0.4mg/ml 2–2.9 minutes
| 2 | Trabeculectomy Antifibrosis agents | Limbus | | | | 0.4mg/ml 2–2.9 minutes
Donoso, Rodriguez, 2000 Chile | 1 | Cataract extraction Antifibrosis agents | | Phaco. Scleral | | | | Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | | Can't Tell
El-Sayyad, Helal, El-Maghraby et al., 1999 Saudi Arabia | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Clear cornea 2-site | | | 0.3mg/ml 5 or more minutes
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.3mg/ml 5 or more minutes
El-Sayyad, Helal, Khalil et al., 1999 Saudi Arabia | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral Clear cornea | | | 0.3mg/ml 4–4.9 minutes
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | 0.3mg/ml 4–4.9 minutes
Gandolfi, Vecchi, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Limbus | Phaco. Clear cornea 2-site
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Clear cornea 2-site | | | | | 25mg 5
Gayton, Van der Karr, Sanders, 1996 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Scleral 1-site | | | 0.2mg/ml 5 or more minutes
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Scleral 2-site | | | 0.2mg/ml 5 or more minutes | | Can't Tell Can't Tell
Gayton, Van der Karr, Sanders, 1999 United States | 1 | Endoscopic laser Cataract extraction | | Phaco. Clear cornea 1-site | | Angle: 240–270 Power: Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | Phaco. 2-site | | | 0.2mg/ml 5 or more minutes | | Can't Tell Can't Tell
Gianoli, Schnyder, Bovey et al., 1999 Europe | 1 | Cataract extraction Deep sclerectomy | | Phaco. Clear cornea 2-site | | | | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction | Limbus | Phaco. Scleral 1-site | | | | | Can't Tell Can't Tell
Gimbel, Meyer, DeBroff et al., 1995 Canada | 1 | Cataract extraction Trabeculotomy Ab external | | Phaco. Scleral
| 2 | Cataract extraction | | Phaco. Scleral
Gunning, Greve, 1991 Europe | 1 | Cataract extraction | | ECCE Clear cornea
Hayashi, Hayashi, Nakao et al., 2000 Asia (Japan) | 1 | Cataract extraction | | Phaco. Clear cornea
| 2 | Cataract extraction | | Phaco. Clear cornea
| 3 | Cataract extraction | | Phaco. Scleral
Hennis, Stewart, 1991 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | ECCE 1-site | | | | | 5mg 14
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE 1-site
Honjo, Tanihara, Negi, et al., 1996 Japan | 1 | Trabeculectomy Cataract extraction | | ECCE Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | | Phaco. Scleral 2-site
| 3 | Trabeculectomy Cataract extraction | | Phaco. Scleral 1-site
Hugkulstone, Sadiq, Rubasingham, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Limbus | ECCE 1-site
| 2 | Trabeculectomy Cataract extraction | Limbus | ECCE 1-site
Hurvitz, 1993 United States | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
| 3 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | | | Can't Tell Can't Tell
Jayamanne, Kostakis, Phelan, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Jerndal, Lundstrom, 1980 Europe | 1 | Trabeculectomy | Fornix
Karlen, Sanchez, Schnyder et al., 1999 Europe | 1 | Antifibrosis agents DSCI | | | | | | | 5mg Can't Tell
Kendrick, Kollarits, Khan, 1996 United States | 1 | Cataract extraction Ab interno sclerostomy | | Phaco. Scleral
| 2 | Trabeculectomy Cataract extraction | Limbus | Phaco. Scleral
Kim, Jung, Hwang, 1998 Korea | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
| 3 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Kitazawa, Suemori-Matsushita, Yamamoto et al., 1993 Japan | 1 | Trabeculectomy Antifibrosis agents | Can't Tell | | | | 0.2mg/ml 5 or more minutes
| 2 | Trabeculectomy Antifibrosis agents | Can't Tell | | | | Can't Tell 5 or more minutes
Kooner, Dulaney, Zimmerman, 1988 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction | | ECCE Clear cornea
| 3 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral
Kosmin, Wishart, Ridges, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
Kosmin, Wishart, Ridges, 1998 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral Clear cornea 1-site 2-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Krupin, Feitl, Bishop, 1989 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Trabeculectomy Cataract extraction Posterior lip Sclerectomy | Limbus | ECCE Scleral
Lamping, Bellows, Hutchinson et al., 1986 United States | 1 | Posterior lip Sclerectomy | Can't Tell
| 2 | Trabeculectomy | Can't Tell
Lemon, Shin, Kim et al., 1998 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.5mg/ml 1–1.9 minute
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | 0.5mg/ml 1–1.9 minute
Lewis, Phelps, 1984 United States | 1 | Trabeculectomy | Fornix
| 2 | Thermosclerostomy
Liu, Su, Chou et al., 2000 Taiwan | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | 0.2mg/ml 3–3.9 minutes
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
Lyle, Jin, 1991 United States | 1 | Trabeculectomy Cataract extraction | Limbus | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction | Limbus | Phaco. 1-site
Mamalis, Lohner, Rand et al., 1996 United States | 1 | Trabeculectomy Antifibrosis agents | Fornix | Phaco. 1-site | | | | | Can't Tell Can't Tell
Manoj, Chako, Khan, 2000 Europe | 1 | Cataract extraction | | ECCE Clear cornea
| 2 | Cataract extraction | | Phaco. Clear cornea
McCartney, Memmen, Stark et al., 1988 United States | 1 | Trabeculectomy Cataract extraction | Can't Tell | ECCE Scleral
McGuigan, Gottsch, Stark et al., 1986 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction | | ECCE Scleral
| 3 | Trabeculectomy Cataract extraction | Can't Tell | ECCE Scleral 1-site
McKinzie, Boggs, 1989 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction | | ECCE Scleral
Montgomery, Gills, 1980 United States | 1 | Cataract extraction Cyclodialysis | Limbus | ECCE Scleral
Murchison, Shields, 1989 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction Guarded Sclerectomy | Can't Tell | ECCE Scleral
| 3 | Trabeculectomy Cataract extraction Posterior lip Sclerectomy | Can't Tell | ECCE Clear cornea
Murchison, Shields, 1990 United States | 1 | Trabeculectomy Cataract extraction | Limbus | ECCE Scleral
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral
Naveh, Kottass, Glovinsky et al., 1990 Israel | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral
| 2 | Trabeculectomy | Fornix | No CE
Neumann, Zalish, Oliver, 1988 Israel | 1 | Trabeculectomy Cataract extraction IOL | Fornix | ECCE Scleral
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral
Nielsen, 1997 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
Noben, Linsen, Zeyen, 1998 Europe | 1 | Trabeculectomy | Limbus | No CE
| 2 | Trabeculectomy Cataract extraction | Limbus | Phaco. 1-site
O'Grady, Juzych, Shin et al., 1993 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Onali, Raitta, 1991 Europe | 1 | Cataract extraction | | ECCE Scleral
Park, Weitzman, Caprioli, 1997 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Clear cornea 2-site | | | | | Can't Tell Can't Tell
| 2 | Trabeculectomy Antifibrosis agents | Limbus | No CE | | | | | Can't Tell Can't Tell
Perasalo, 1997 Europe | 1 | Cataract extraction | | Phaco. Scleral
Robin, 1993 United States | 1 | Trabeculectomy Cataract extraction Other medications | Fornix | ECCE Scleral
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral
Robin, Ramakrishnan, Krishnadas, et al., 1997 India | 1 | Trabeculectomy | Fornix
| 2 | Trabeculectomy Antifibrosis agents | Fornix | | | | 0.2mg/ml 2–2.9 minutes
| 3 | Trabeculectomy Antifibrosis agents | Fornix | | | | 0.2mg/ml 4–4.9 minutes
| 4 | Trabeculectomy Antifibrosis agents | Fornix | | | | 0.4mg/ml 2–2.9 minutes
Rossetti, Bucci, Miglior et al., 1997 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Clear cornea
Sanders, Cantor, Dobler et al., 1999 United States | 1 | Trabeculectomy Antifibrosis agents | Limbus | | | | 0.2mg/ml 2–2.9 minutes
| 2 | Trabeculectomy Antifibrosis agents | Limbus | | | | 0.4mg/ml 2–2.9 minutes
Savage, Thomas, Belcher et al., 1985 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction | | ECCE Scleral
| 3 | Trabeculectomy Cataract extraction Other glaucoma surgery | Can't Tell | ECCE Scleral
Shin, Kim, Sheth et al., 1998 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. | | | 0.5mg/ml 1–1.9 minute
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco.
Shin, Ren, Juzych et al., 1998 United States | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. 1-site | | | 0.5mg/ml Can't Tell
Shin, Kim, Ren et al., 1998 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | 0.5mg/ml Can't Tell
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Shingleton, Jacobson, Kuperwaser, 1995 United States | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Shingleton, Gamell, O'Donoghue et al., 1999 United States | 1 | Cataract extraction | | Phaco. Clear cornea
| 2 | Cataract extraction | | Phaco. Clear cornea
| 3 | Cataract extraction | | Phaco. Clear cornea
Shingleton, Chaudhry, O'Donoghue et al., 1999 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. Scleral 1-site | | | 0.4mg/ml 1–1.9 minute | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site | | | 0.4mg/ml 1–1.9 minute | | Can't Tell Can't Tell
Spaeth, 1980 United States | 1 | Trabeculectomy | Can't Tell
| 2 | Thermal sclerostomy | Can't Tell
Stewart, Crinkley, Carlson, 1994a United States | 1 | Trabeculectomy Cataract extraction | Limbus | Phaco. Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Stewart, Crinkley, Carlson, 1994b United States | 1 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 1-site
Storr-Paulsen, Pedersen, Laugesen, 1998 Europe | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral | | | | | Can't Tell Can't Tell
| 2 | Cataract extraction | | Phaco. Scleral
Tanihara, Negi, Akimoto et al., 1993 Japan | 1 | Trabeculectomy | Limbus
Tezel, Kolker, Kass et al., 1997a United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Limbus | Phaco. 1-site | | | 0.2mg/ml 2–2.9 minutes | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents Other medications | Fornix | Phaco. 1-site | | | 0.2mg/ml 2–2.9 minutes | | Can't Tell Can't Tell
Tezel, Kolker, Kass et al., 1997b United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | ECCE 1-site | | | 0.2mg/ml 2–2.9 minutes | | Can't Tell Can't Tell
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | Phaco. 1-site | | | 0.2mg/ml 2–2.9 minutes | | Can't Tell Can't Tell
Tornqvist, Drolsum, 1991 Europe | 1 | Trabeculectomy | Can't Tell
Tuulonen, Niva, Alanko, 1987 Europe | 1 | Trabeculoplasty | | | WaveLength: Can't Tell Angle: 360° Power: Can't Tell
| 2 | Other medications
Vu and Shields, 1988 United States | 1 | Cataract extraction | | ECCE Scleral
| 2 | Cataract extraction | | ICCE Scleral
Vyas, Bacon, Percival, 1998 Europe | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Fornix | Phaco. Scleral 1-site
Wand, 1996 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.5mg/ml 3–3.9 minutes
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.5mg/ml 3–3.9 minutes
Watson, Jakeman, Ozturk et al., 1990 Europe | 1 | Trabeculectomy | Can't Tell
Wedrich, Menapace, Hirsch et al., 1996 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. 1-site
West, Burke, Cunliffe et al., 1992 Europe | 1 | Cataract extraction | | ECCE Clear cornea
| 2 | Cataract extraction | | ECCE Clear cornea
| 3 | Cataract extraction | | ECCE Clear cornea
Wilson, 1989 St. Lucia | 1 | Posterior sclerectomy
| 2 | Trabeculectomy | Limbus
Wishart, Austin, 1993 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE Scleral 1-site
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Wong, Ruderman, Krupin et al., 1994 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | ECCE Scleral Can't Tell | | | | | 5mg 5
| 2 | Trabeculectomy Cataract extraction | Can't Tell | ECCE Scleral Can't Tell
Wyse, Meyer, Ruderman et al., 1998 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 1-site | | | 0.4mg/ml 2–2.9 minutes
| 2 | Trabeculectomy Cataract extraction Antifibrosis agents | Limbus | Phaco. 2-site | | | 0.4mg/ml 2–2.9 minutes
Yalvac, Airaksinen, Tuulonen, 1997 Europe | 1 | Cataract extraction | | Phaco. Scleral
| 2 | Trabeculectomy Cataract extraction | Fornix | Phaco. Scleral 1-site
Yang, Moster, Azuara-Blanco et al., 1997 United States | 1 | Trabeculectomy Cataract extraction Antifibrosis agents | Can't Tell | Phaco. Scleral 1-site | | | 0.4mg/ml Can't Tell
Yu, Chong, Caesar et al., 1996 Europe | 1 | Trabeculectomy Cataract extraction | Fornix | ECCE 2-site
| 2 | Trabeculectomy | Fornix | No CE

Evidence Table 3. Methodologic quality of literature on treatment of coexisting cataract and glaucoma

| | | Quality Score
| | | Representativeness (Questions 12–15) | Bias (Questions 16–19) | Description of Therapy (Questions 20–24) | Outcomes (Questions 25–28) | Statistical Analysis (Questions 29–32) | Overall Quality Score
Study Information (Author, Year; Location) | Study Design | Exclusion Criteria | % | % | % | % | % | %
Advanced Glaucoma Intervention Study, The (AGIS):, 1998 United States | RCT | Less than maximal medical therapy for glaucoma; | 88 | 50 | 58 | 55 | 100 | 70
Anand, Menage, Bailey, 1997 Europe | Cohort | None stated | 25 | 0 | 0 | 50 | 67 | 28
Anders, Pham, Holschbach et al., 1997 Europe | RCT | IOP <21 mmHg | 19 | 50 | 83 | 83 | 100 | 67
Arnold, 19960 United States | Cohort | None stated | 75 | 0 | 50 | 58 | 0 | 37
Bellucci, Perfetti, Babighian et al., 1997 Europe | Cohort | None stated | 13 | 0 | 33 | 25 | 33 | 21
Bellucci, Luraschi, 1998 Europe | NRCT | None stated | 19 | 33 | 17 | 17 | 33 | 24
Berestka, Brown, 1997 United States | Cohort | Followup < 6 months | 63 | 0 | 67 | 58 | 50 | 48
Blondeau, Phelps, 1981 United States | RCT | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Ocular injury; Other ocular surgery | 88 | 67 | 58 | 63 | 100 | 75
Bobrow, 1998 United States | RCT | Previous cataract surgery; Asymmetric glaucoma | 75 | 67 | 83 | 83 | 100 | 82
Borggrefe, Lieb, Grehn, 1999 Europe | RCT | Other intraocular surgery except LTP | 88 | 50 | 67 | 42 | 75 | 64
Budenz, Pyfer, Singh et al., 1999 United States | Cohort | Previous cataract surgery | 63 | 17 | 33 | 75 | 100 | 58
Caprioli, Park, Weitzman, 1996 United States | Cohort | Inflammatory glaucoma; Neovascular glaucoma; Angle closure glaucoma | 88 | 50 | 100 | 75 | 100 | 83
Carlson, Alward, Barad et al., 1997 United States | RCT | Previous cataract surgery; Coexisting ocular disease | 88 | 50 | 100 | 58 | 100 | 79
Chia, Goldberg, 1998 Australia | Cohort | None stated | 83 | 0 | 58 | 33 | 75 | 50
Cohen, 1990 United States | Cohort | If IOP controlled by less than maximal therapy | 63 | 33 | 92 | 17 | 100 | 61
Cohen, Greff, Novack et al., 1996 United States | RCT | Previous glaucoma laser surgery; Inflammatory glaucoma; Neovascular glaucoma; History of incisional surgery | 88 | 83 | 92 | 33 | 80 | 69
Collaborative Normal-Tension Glaucoma Study Group, 1998a United States | RCT | Age < 20; Inflammatory glaucoma; Neovascular glaucoma; Narrow angle | 75 | 33 | 50 | 75 | 100 | 67
Collaborative Normal-Tension Glaucoma Study Group, 1998b United States | RCT | Age < 20; Inflammatory glaucoma; Neovascular glaucoma; Narrow angle | 75 | 33 | 50 | 75 | 100 | 67
Crestani, De Natale, Steindler, 1997 Europe | Cohort | None stated | 13 | 0 | 0 | 0 | 0 | 3
Dastur, 1994 India | NRCT | Unilateral glaucoma or advanced visual field changes; Low tension glaucoma; Prior topical therapies for glaucoma; Diabetes | 75 | 0 | 75 | 69 | 0 | 44
Demailly, Kretz, 1992 Europe | RCT | None stated | 50 | 33 | 42 | 0 | 50 | 35
Derick, Evans, Baker, 1998 United States | Cohort | None stated | 88 | 0 | 100 | 58 | 67 | 63
El-Sayyad, Helal, El-Maghraby et al., 1999 Saudi Arabia | RCT | Corneal opacities; Posterior segment disorder; Cataracts too dense for phacoemulsification | 88 | 67 | 33 | 67 | 50 | 61
Gandolfi, Vecchi, 1997 Europe | RCT | Previous cataract surgery | 25 | 50 | 100 | 67 | 67 | 62
Gayton, Van der Karr, Sanders, 1996 United States | Cohort | None stated | 38 | 0 | 50 | 33 | 33 | 31
Gayton, Van der Karr, Sanders, 1999 United States | RCT | None stated | 44 | 33 | 92 | 50 | 33 | 50
Gianoli, Schnyder, Bovey et al., 1999 Europe | RCT | Previous glaucoma surgery; Inflammatory glaucoma; Neovascular glaucoma; Secondary glaucoma | 63 | 50 | 100 | 33 | 50 | 59
Gimbel, Meyer, DeBroff et al., 1995 Canada | RCT | Neovascular glaucoma; Previous intraocular surgery; Advanced glaucoma; IOP > 27, or proliferative diabetic retinopathy | 75 | 33 | 92 | 67 | 50 | 63
Hayashi, Hayashi, Nakao et al., 2000 Japan | Cohort | Ocular Hypertension; Secondary glaucoma | 86 | 33 | 33 | 50 | 50 | 50
Hennis, Stewart, 1991 United States | RCT | None stated | 75 | 33 | 75 | 50 | 17 | 50
Honjo, Tanihara, Negi et al., 1996 Japan | Cohort | None stated | 0 | 0 | 17 | 33 | 17 | 13
Hugkulstone, Sadiq, Rubasingham, 1997 Europe | RCT | None stated | 31 | 67 | 17 | 67 | 100 | 56
Hurvitz, 1993 United States | Cohort | Previous glaucoma surgery; Chronic angle closure glaucoma; Uveitic glaucoma | 50 | 0 | 33 | 50 | 33 | 33
Kendrick, Kollarits, Khan, 1996 United States | Cohort | None stated | 19 | 0 | 17 | 33 | 33 | 20
Kim, Jung, Hwang, 1998 Korea | RCT | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Congenital or secondary glaucoma; Any past eye surgery | 63 | 17 | 67 | 50 | 33 | 46
Kitazawa, Suemori-Matsushita, Yamamoto et al., 1993 Japan | RCT | Previous intraocular surgery; Asymmetric ocular conditions | 63 | 50 | 100 | 50 | 100 | 73
Kosmin, Wishart, Ridges, 1997 Europe | Cohort | None stated | 94 | 33 | 33 | 67 | 75 | 60
Kosmin, Wishart, Ridges, 1998 Europe | Cohort | None stated | 31 | 17 | 100 | 33 | 67 | 50
Krupin, Feitl, Bishop, 1989 United States | RCT | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Narrow angle | 63 | 17 | 50 | 75 | 67 | 54
Lemon, Shin, Kim et al., 1998 United States | RCT | Secondary glaucoma; Previous ocular incisional surgery | 63 | 50 | 92 | 75 | 50 | 66
Lewis, Phelps, 1984 United States | RCT | Previous glaucoma laser surgery; Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Ocular injury (not open angle); Other ocular surgery. | 88 | 67 | 58 | 69 | 100 | 76
Liu. Su, Chou et al., 2000 Taiwan | Cohort | Previous intraocular surgery; Incomplete followup; Intraoperative vitreous loss | 75 | 17 | 92 | 58 | 75 | 63
Lyle, Jin, 1991 United States | Cohort | Inadequate followup | 81 | 33 | 83 | 21 | 100 | 64
Manoj, Chako, Khan, 2000 Europe | Cohort | Previous trabeculectomy with antimetabolites or other non- trabeculectomy filtering surgery; Secondary glaucoma or angle closure glaucoma; Intraoperative complications; Followed < 6 months | 63 | 0 | 14 | 57 | 33 | 33
McGuigan, Gottsch, Stark et al., 1986 United States | Cohort | Incomplete followup | 38 | 0 | 92 | 43 | 25 | 40
McKinzie, Boggs, 1989 United States | Cohort | Cataract extraction by phacoemulsification | 6 | 0 | 83 | 60 | 0 | 30
Murchison, Shields, 1989 United States | Cohort | None stated | 69 | 0 | 100 | 50 | 0 | 44
Murchison, Shields, 1990 United States | Cohort | None stated | 50 | 33 | 100 | 50 | 100 | 67
Naveh, Kottass, Glovinsky et al., 1990 Israel | Cohort | Previous glaucoma surgery | 88 | 0 | 33 | 50 | 67 | 48
Neumann, Zalish, Oliver, 1988 Israel | Cohort | Inflammatory glaucoma; High myopia; Advanced proliferative diabetic retinopathy; Uveitis | 63 | 0 | 33 | 43 | 33 | 34
Nielsen, 1997 Europe | NRCT | None stated | 33 | 0 | 17 | 43 | 50 | 29
O'Grady, Juzych, Shin et al., 1993 United States | RCT | None stated | 31 | 50 | 83 | 29 | 33 | 45
Park, Weitzman, Caprioli, 1997 United States | Cohort | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Acute ACG | 63 | 17 | 100 | 50 | 83 | 63
Robin, 1993 United States | RCT | Previous glaucoma laser surgery; Inflammatory glaucoma; Neovascular glaucoma | 75 | 83 | 67 | 57 | 100 | 67
Robin, Ramakrishnan, Krishnadas et al., 1997 India | RCT | Neovascular glaucoma; Prior intraocular surgery; Chronic uveitis; VA <10/200 | 75 | 67 | 100 | 50 | 100 | 78
Rossetti, Bucci, Miglior et al., 1997 Europe | RCT | None stated | 19 | 17 | 0 | 0 | 17 | 11
Sanders, Cantor, Dobler et al., 1999 United States | RCT | Age < 21; Inflammatory glaucoma; Neovascular glaucoma; Pregnancy | 88 | 83 | 100 | 71 | 100 | 88
Savage, Thomas, Belcher et al., 1985 United States | Cohort | Age < 50; Trauma; Diabetes; Known ocular pathology besides glaucoma | 81 | 0 | 33 | 14 | 17 | 29
Shin, Kim, Sheth et al., 1998 United States | RCT | None stated | 38 | 33 | 58 | 71 | 67 | 53
Shin, Ren, Juzych et al., 1998 United States | RCT | Previous cataract surgery; Glaucoma other than open angle | 63 | 83 | 100 | 71 | 75 | 78
Shin, Kim, Ren et al., 1998 United States | RCT | Previous glaucoma laser surgery; Previous ocular incisional surgery | 75 | 50 | 92 | 71 | 100 | 78
Shingleton, Jacobson, Kuperwaser, 1995 United States | Cohort | Inflammatory glaucoma; Neovascular glaucoma; Mature or densely brunescent cataracts; Low tension glaucoma; Angle closure glaucoma | 44 | 0 | 100 | 36 | 50 | 46
Shingleton, Chaudhry, O'Donoghue et al., 1999 United States | NRCT | None stated | 38 | 33 | 100 | 60 | 83 | 63
Shingleton, Gamell, O'Donoghue et al., 1999 United States | Cohort | None stated | 69 | 0 | 92 | 57 | 75 | 59
Spaeth, 1980 United States | RCT | None stated | 19 | 17 | 42 | 30 | 0 | 22
Stewart, Crinkley, Carlson, 1994b United States | Cohort | Neovascular glaucoma; Angle closure glaucoma; Congenital glaucoma | 19 | 17 | 42 | 50 | 50 | 36
Storr-Paulsen, Pedersen, Laugensen, 1998 Europe | RCT | Previous cataract surgery; Inflammation; Corneal dystrophy; Diabetes; Systemic steroids or beta blockers | 75 | 50 | 92 | 43 | 100 | 72
Tezel, Kolker, Kass et al., 1997a United States | Cohort | None stated | 38 | 33 | 50 | 29 | 50 | 40
Tezel, Kolker, Kass et al., 1997b United States | Cohort | Eyes with intraoperative complications | 38 | 50 | 42 | 29 | 83 | 48
Tuulonen, Niva, Alanko, 1987 Europe | NRCT | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma | 50 | 33 | 33 | 65 | 100 | 56
Vu, Shields, 1988 United States | NRCT | Other intraocular surgery | 38 | 0 | 83 | 57 | 0 | 36
Vyas, Bacon, Percival, 1998 Europe | NRCT | None stated | 50 | 0 | 58 | 29 | 33 | 34
Wand, 1996 United States | Cohort | None stated | 63 | 17 | 92 | 14 | 100 | 57
Wedrich, Menapace, Hirsch et al., 1996 Europe | Cohort | None stated | 25 | 33 | 50 | 57 | 50 | 43
West, Burke, Cunliffe et al., 1992 Europe | RCT | Previous cataract surgery | 44 | 83 | 83 | 60 | 75 | 69
Wilson, 1989 St. Lucia | RCT | None stated | 63 | 50 | 100 | 55 | 100 | 74
Wishart, Austin, 1993 Europe | Cohort | Less than maximal medical treatment for glaucoma | 63 | 33 | 92 | 33 | 50 | 54
Wong, Ruderman, Krupin et al., 1994 United States | RCT | Previous glaucoma laser surgery; Previous intraocular surgery; Intraocular inflammation or corneal disease | 75 | 67 | 58 | 43 | 67 | 62
Wyse, Meyer, Ruderman et al., 1998 United States | RCT | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma | 75 | 50 | 92 | 50 | 33 | 60
Yalvac, Airaksinen, Tuulonen, 1997 Europe | Cohort | Previous cataract surgery; Inflammatory glaucoma; Neovascular glaucoma; Patients using topical steroids | 63 | 0 | 58 | 43 | 67 | 46
Yu, Chong, Caesar et al., 1996 Europe | Cohort | Age < 60; Previous ocular surgery; Use of ocular hypertensives; Normal tension glaucoma | 88 | 17 | 83 | 36 | 100 | 65

Evidence Table 4. What is the effect of cataract surgery (with or without other procedures/treatments) on long-term intraocular pressure control in open-angle glaucoma patients?

| | | | | | | | Outcomes/Benefits of Surgery
Study Information (Author, Year, Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Surgical Interventions | Proportion of Eyes with Pupil Manipulation | Number of Eyes at Reported Followup | Mean IOP Change | # Eyes with 30% Reduction IOP | # Eyes with IOP ≤ 21mm Hg | # Achieving Target IOP | Mean # of Medications | # Eyes Needing Medications
Study design: Randomized controlled trials
Anders, Pham, Holschbach et al., 1997 Europe Followup: 12 to 23 months Quality: 67% | 1 | 43 | NR | NR | Filter (radial incision) Phaco. Scleral 1-site | 0.05 | 42 | -7.70 | NR | NR | NR | 0.12 | 8
| 2 | 42 | NR | NR | Phaco. Scleral | 0.00 | 41 | -3.70 | NR | NR | NR | 1.00 | 28
Bobrow, 1998 United States Followup: ≥ 24 months Quality: 82% | 1 | 35 | 0.14 | 0 | Trab. ECCE Scleral | NR | 35 | -8.20 | NR | NR | NR | 0.17 | 6
| 2 | 35 | 0.14 | 0 | ECCE Scleral | NR | 35 | -4.30 | NR | NR | NR | 0.77 | 21
Gimbel, Meyer, DeBroff et al., 1995 Canada Followup: 12 to 23 months Quality: 63% | 1 | 53 | NR | 0 | Trab. Phaco. Scleral | NR | 51 | -6.10 | NR | NR | NR | NR | 28
| 2 | 53 | NR | 0 | Phaco. Scleral | NR | 51 | -3.80 | NR | NR | NR | NR | 45
Hugkulstone, Sadiq, Rubasingham, 1997 Europe Followup: ≥ 24 months Quality: 56% | 1 | 9 | NR | NR | Trab. ECCE 1-site Standard IOL | NR | 7 | -3.80 | NR | NR | NR | 0.00 | NR
| 2 | 10 | NR | NR | Trab. ECCE 1-site Heparin-coated IOL | NR | 9 | -9.70 | NR | NR | NR | 0.10 | NR
Kim, Jung, Hwang, 1998 Korea Followup: Not Reported Quality: 46% | 1 | 11 | 0.00 | 0 | Trab. Phaco. Scleral 1-site No stitch | NR | 11 | -3.37 | NR | NR | NR | NR | NR
| 2 | 8 | 0.00 | 0 | Trab. Phaco. Scleral 1-site T-incision | NR | 8 | -4.88 | NR | NR | NR | NR | NR
| 3 | 9 | 0.00 | 0 | Trab. Phaco. Scleral 1-site | NR | 9 | -11.44 | NR | NR | NR | NR | NR
Storr-Paulsen, Pedersen, Laugesen, 1998 Europe Followup: 6 to 11 months Quality: 72% | 1 | 10 | NR | 0 | Trab. Phaco. Scleral | NR | 10 | NR | NR | NR | 10 | 0.00 | NR
| 2 | 10 | NR | 0 | Phaco. Scleral | NR | 10 | NR | NR | NR | 10 | 1.00 | NR
Study design: Non-randomized controlled trials
Nielsen, 1997 Europe Followup: 12 to 23 months Quality: 29% | 1 | 10 | NR | NR | Trab. Phaco. 1-site | NR | Can't Tell | -14.00 | NR | NR | NR | 0.50 | NR
| 2 | 26 | NR | NR | Trab.(more posterior) Phaco. 1-site | NR | Can't Tell | -8.00 | NR | NR | NR | 0.10 | NR
Shingleton, Chaudhry, O'Donoghue et al., 1999 United States Followup: Not Reported Quality: 63% | 1 | 44 | 0.00 | NR | Trab. Limbus Phaco. Scleral 1-site | 0.32 | 44 | -6.13 | NR | NR | NR | 0.16 | NR
| 2 | 44 | 0.00 | NR | Trab. Fornix Phaco. Scleral 1-site | 0.39 | 44 | -6.13 | NR | NR | NR | 0.20 | NR
Vyas, Bacon, Percival, 1998 Europe Followup: 12 to 23 months Quality: 34% | 1 | 25 | 0.00 | NR | Phaco. Scleral 1-site PMMA lens | 0.24 | Can't Tell | -7.80 | NR | NR | NR | NR | NR
| 2 | 25 | 0.00 | NR | Phaco. Scleral 1-site Silicone lens | 0.44 | Can't Tell | -7.60 | NR | NR | NR | NR | NR
Study design: Cohort studies
Arnold, 1996 United States Followup: Not Reported Quality: 37% | 1 | 20 | NR | NR | Trab. Phaco. Scleral 1-site 2-stitch | NR | Can't Tell | -8.0 | NR | 20 | NR | 0.20 | 4
| 2 | 20 | NR | NR | Trab. Phaco. Scleral 1-site No-stitch | NR | Can't Tell | -7.5 | NR | 20 | NR | 0.10 | 2
Bellucci, Perfetti, Babighian et al., 1997 Europe Followup: Not Reported Quality: 21% | 1 | 100 | NR | NR | Trab. No CE | NR | 75 | -11.20 | NR | NR | NR | 0.47 | NR
| 2 | 200 | NR | NR | Trab. Phaco. Scleral 1-site | NR | 118 | -3.10 | NR | NR | NR | 0.16 | NR
Berestka, Brown, 1997 United States Followup: Not Reported Quality: 48% | 1 | 28 | 0.00 | NR | Trab. Limbus Phaco. 1-site | 0.61 | Can't Tell | -8.20 | NR | NR | NR | NR | NR
| 2 | 24 | 0.00 | NR | Trab. Fornix Phaco. 1-site | 0.42 | Can't Tell | -7.80 | NR | NR | NR | NR | NR
Caprioli, Park, Weitzman, 1996 United States Followup: 12 to 23 months Quality: 83% | 1 | 40 | 0.08 | 0 | Trab. Phaco. 2-site | 0.22 | 39 | -7.40 | NR | NR | 28 | 0.50 | NR
| 2 | 40 | 0.00 | 0 | Trab. No CE | NR | 40 | -10.30 | NR | NR | 35 | 0.40 | NR
Crestani, De Natale, Steindler, 1997 Europe Followup: Not Reported Quality: 3% | 1 | NR | NR | NR | Trab. Phaco. 1-site Punch technique | NR | Can't Tell | -12.60 | NR | NR | NR | NR | NR
| 2 | NR | NR | NR | Trab. Phaco. 1-site “Cairns” technique | NR | Can't Tell | -14.20 | NR | NR | NR | NR | NR
Derick, Evans, Baker, 1998 United States Followup: 12 to 23 months Quality: 63% | 1 | 42 | 0.11 | NR | Trab. Phaco. Scleral | NR | Can't Tell | -8.90 | 26 | 40 | NR | 0.38 | 15
| 2 | 42 | 0.12 | NR | Trab. No CE | NR | Can't Tell | -10.60 | 32 | 39 | NR | 0.50 | 14
Hayashi, Hayashi, Nakao et al., 2000 Asia (Japan) Followup: 12 to 23 months Quality: 50% | 1 | 77 | NR | NR | Phaco.^1^ Clear cornea | NR | Can't Tell | -6.40 | NR | NR | NR | NR | NR
| 2 | 73 | NR | NR | Phaco.^2^ Clear cornea | NR | Can't Tell | -4.10 | NR | NR | NR | NR | NR
| 3 | 74 | NR | NR | Phaco.^3^ Scleral | NR | Can't Tell | -1.00 | NR | NR | NR | NR | NR
Honjo, Tanihara, Negi et al., 1996 Japan Followup: Not Reported Quality: 13% | 1 | 25 | NR | NR | Trab. ECCE Scleral 1-site | NR | 23 | -9.60 | NR | 15 | NR | 1.10 | NR
| 2 | 10 | NR | NR | Trab. Phaco. Scleral 2-site | NR | 8 | -7.40 | NR | 6 | NR | 0.60 | NR
Honjo, Tanihara, Negi et al., 1996 Japan Reference No.: 188 Quality: 13% | 3 | 12 | NR | NR | Trab. Phaco. Scleral 1-site | NR | 5 | -11.60 | NR | 6 | NR | 1.40 | NR
Kosmin, Wishart, Ridges et al., 1997 Europe Followup: 12 to 23 months Quality: 60% | 1 | 30 | NR | NR | Phaco. 1-site Silicone lens | 0.40 | 30 | -7.70 | NR | 30 | NR | 1.71 | 6
| 2 | 30 | NR | NR | Phaco. 1-site PMMA lens | 0.43 | 30 | -6.60 | NR | 30 | NR | 1.33 | 7
Lyle, Jin, 1991 United States Followup: 12 to 23 months Quality: 64% | 1 | 104 | NR | NR | Phaco. 1-site 3mm incision | NR | 104 | -8.90 | NR | 102 | NR | 0.20 | 22
| 2 | 112 | NR | NR | Phaco. 1-site 6mm incision | NR | 112 | -6.80 | NR | 105 | NR | 0.40 | 42
Manoj, Chako, Khan, 2000 Europe Followup: ≥ 24 months Quality: 33% | 1 | 34 | NR | NR | ECCE Clear cornea | NR | Can't Tell | +0.28 | NR | 33 | NR | NR | 7
| 2 | 21 | NR | NR | Phaco. Clear cornea | NR | Can't Tell | -0.56 | NR | 21 | NR | NR | 0
McGuigan, Gottsch, Stark et al., 1986 United States Followup: 12 to 23 months Quality: 40% | 1 | 40 | NR | NR | ECCE Fornix Scleral^4^ | NR | Can't Tell | NR | NR | NR | NR | 1.14 | 32
| 2 | 40 | NR | NR | ECCE Scleral^5^ | NR | Can't Tell | NR | NR | NR | NR | 1.00 | 0
| 3 | 10 | NR | NR | ECCE Scleral^6^ 1-site | NR | Can't Tell | NR | NR | NR | NR | NR | 5
Murchison, Shields, 1990 United States Followup: 12 to 23 months Quality: 67% | 1 | 22 | 0.23 | NR | Trab. Limbus ECCE Scleral | NR | Can't Tell | -3.30 | NR | NR | NR | NR | 18
| 2 | 25 | 0.12 | NR | Trab. Fornix ECCE Scleral | NR | Can't Tell | -2.70 | NR | NR | NR | NR | 23
Naveh, Kottass, Glovinsky et al., 1990 Israel Followup: 12 to 23 months Quality: 48% | 1 | 40 | NR | 0 | Trab. ECCE Scleral | NR | Can't Tell | -8.00 | NR | 18 | NR | 2.31 | 32
| 2 | 38 | NR | 0 | Trab. No CE | NR | Can't Tell | -14.70 | NR | 20 | NR | 0.55 | 14
Neumann, Zalish, Oliver, 1988 Israel Followup: 6 to 11 months Quality: 36% | 1 | 23 | NR | NR | Trab. ECCE Scleral IOL | NR | Can't Tell | -6.27 | NR | NR | NR | NR | 13
| 2 | 23 | NR | NR | Trab. ECCE Scleral No IOL | NR | Can't Tell | -6.47 | NR | NR | NR | NR | 9
Savage, Thomas, Belcher et al., 1985 United States Followup: Not Reported Quality: 29% | 1 | 127 | NR | NR | ECCE^7^ Scleral | NR | 38 | -0.80 | NR | NR | NR | 6.10 | NR
| 2 | 157 | NR | NR | ECCE^8^ Scleral | 0.04 | 45 | -0.60 | NR | NR | NR | 0.00 | NR
| 3 | 12 | NR | NR | Trab.^9^ ECCE Scleral | NR | Can't Tell | NR | NR | NR | NR | NR | NR
Shingleton, Gamell, O'Donoghue et al., 1999 United States Followup: Not Reported Quality: 59% | 1 | 164 | NR | 0 | Phaco.^10^ Clear cornea | 0.00 | 164 | -2.05 | NR | NR | NR | 0.00 | NR
| 2 | 75 | NR | 0 | Phaco.^11^ Clear cornea | 0.01 | 75 | -1.91 | NR | NR | NR | 0.00 | NR
| 3 | 71 | NR | 0 | Phaco.^12^ Clear cornea | 0.07 | 71 | -1.11 | NR | NR | NR | 0.65 | NR
Tezel, Kolker, Kass et al., 1997a United States Followup: 12 to 23 months Quality: 40% | 1 | 151 | 0.14 | NR | Trab. Limbus Phaco. 1-site | NR | 151 | -8.10 | NR | 95 | NR | NR | 56
| 2 | 64 | 0.10 | NR | Trab. Fornix Phaco. 1-site | NR | 64 | -8.10 | NR | 32 | NR | NR | 32
Wand, 1996 United States Followup: 6 to 11 months Quality: 57% | 1 | 24 | 0.14 | NR | Phaco. 1-site 6mm incision | NR | Can't Tell | -7.30 | NR | 19 | NR | 0.60 | 8
| 2 | 33 | 0.19 | NR | Phaco. 1-site 3mm incision | NR | Can't Tell | -9.10 | NR | 28 | NR | 0.50 | 11
Yalvac, Airaksinen, Tuulonen, 1997 Europe Followup: Not Reported Quality: 46% | 1 | 35 | NR | 0 | Phaco. Scleral | NR | 35 | -3.40 | NR | NR | NR | 1.00 | 26
| 2 | 21 | NR | 0 | Trab. Phaco. Scleral 1-site | NR | 21 | -6.80 | NR | NR | NR | 1.00 | 15
Yu, Chong, Caesar et al., 1996 Europe Followup: 12 to 23 months Quality: 65% | 1 | 21 | 0.00 | 0 | ECCE 2-site | NR | 21 | -7.50 | NR | 21 | NR | 0.57 | 8
| 2 | 24 | 0.00 | 0 | Trab. No CE | NR | 24 | -11.40 | NR | 24 | NR | 0.35 | 6
Study design: Clinical series
Bloomberg, 1996 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | NR | NR | NR | Phaco. 1-site | NR | 53 | -5.10 | NR | NR | NR | 0.20 | NR
Burratto, Ferrari, 1990 Europe Followup: 6 to 11 months Quality: Not Applicable | 1 | 104 | NR | NR | Phaco. scleral | NR | 104 | 0.00 | NR | 103 | NR | NR | 26
Calissendorff, Hamberg-Nystrom, 1992 Europe Followup: ≥ 24 months Quality: Not Applicable | 1 | 113 | NR | NR | ECCE Scleral | NR | 74 | -2.60 | NR | NR | NR | 0.68 | 32
Chen, Weaver, Budenz et al., 1998 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 115 | 0.15 | 1.16 | Phaco. ECCE Scleral Clear cornea | 0.5 | Can't Tell | 2.4 | NR | NR | NR | NR | 32
Cinotti, Fiore, Maltzman et al., 1998 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 160 | NR | NR | ECCE Scleral | NR | 116 | -1.40 | NR | NR | NR | 1.00 | NR
Crandall, 1991 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 100 | 0.02 | NR | Trab. Phaco. 1-site | NR | Can't Tell | NR | NR | NR | NR | NR | 64
Gunning, Greve, 1991 Europe Followup: 12 to 23 months Quality: Not Applicable | 1 | 102 | NR | 0.32 | ECCE Clear cornea | NR | 102 | -5.20 | NR | NR | NR | 0.59 | NR
Jayamanne, Kostakis, Phelan, 1997 Europe Followup: 6 to 11 months Quality: Not Applicable | 1 | 100 | NR | NR | Trab. Phaco. Scleral 1-site | NR | Can't Tell | -7.60 | NR | NR | NR | 0.10 | 14
Kooner, Dulaney, Zimmerman, 1988 United States Followup: Not Reported Quality: Not Applicable | 1 | 91 | NR | NR | ECCE Scleral | NR | 64 | -2.20 | NR | NR | NR | NR | 90
| 2 | 9 | NR | NR | Previous Trab. ECCE Clear cornea | NR | 9 | 0.00 | NR | NR | NR | NR | 4
| 3 | 3 | NR | NR | Trab. ECCE Scleral | NR | 3 | -2.70 | NR | NR | NR | NR | 3
McCartney, Memmen, Stark et al. 1988 United States Followup: Not Reported Quality: Not Applicable | 1 | 108 | NR | 0 | Trab. ECCE Scleral | NR | 102^13^ | -6.20 | NR | NR | 62 | 0.48 | 43
Montgomery, Gills, 1980 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 238 | NR | NR | ECCE Scleral | NR | 238 | NR | NR | NR | 207 | NR | 109
Onali, Raitta, 1991 Europe Followup: ≥ 24 months Quality: Not Applicable | 1 | 103 | NR | 0 | ECCE Scleral | 0.25 | 72 | -1.50 | NR | NR | NR | NR | 45
Perasalo, 1997 Europe Followup: Not Reported Quality: Not Applicable | 1 | 226 | NR | NR | Phaco. Scleral | NR | 127 | -1.80 | NR | NR | NR | 0.90 | NR
Yang, Moster, Azuara-Blanco et al., 1997 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 182 | 0.12 | NR | Trab. Phaco. Scleral 1-site | NR | 175 | -7.40 | NR | 167 | NR | 0.30 | 35

1 ACG patients.

2 OAG patients.

3 Controls.

4 Glaucoma patients.

5 Non-glaucoma patients.

6 Glaucoma suspects.

7 Glaucoma patients.

8 Non-glaucoma patients.

9 Glaucoma patients.

10 Non-glaucoma patients.

11 Glaucoma suspects.

12 Glaucoma patients.

13 Last followup IOP was reported at 1.5 years; last followup glaucoma medications at 1 year.

Evidence Table 5. What is the effect of cataract surgery (with or without other procedures/treatments) on short-term intraocular pressure control in open-angle glaucoma patients?

| | | | | | | | | | Outcomes/Benefits of Surgery
Study Information (Author, Year; Location; Mean Followup; Quality Score) | Study Groups | Number of Eyes | Proportion of Patients | Mean Number of Prior | Surgical Interventions | Proportion of Eyes | Intraoperative IOP Medications | Intraoperative Viscoelastic | Postoperative IOP Medications | Mean IOP Change | # Eyes 0–10 mmHg | # Eyes 11–20 mmHg | # Eyes >20 mmHg | # Eyes IOP | # Eyes IOP | # Eyes IOP | # Eyes IOP >40 mmHg
Study design: Randomized controlled trials
Gimbel, Meyer, DeBross et al., 1995 Canada Followup: 12 to 23 months Quality: 63% | 1 | 53 | NR | 0 | Trab. Phaco. Scleral | NR | None | No | None | -2.20 | NR | NR | NR | NR | NR | NR | NR
| 2 | 53 | NR | 0 | Phaco. Scleral | NR | None | No | None | -2.00 | NR | NR | NR | NR | NR | NR | NR
Krupin, Feitl, Bishop, 1989 United States Followup: ≤ 24 hours Quality: 54% | 1 | 26 | 0.23 | 0 | ECCE Scleral | NR | None | Yes | None | +0.6 | 5 | 6 | 11 | 4 | 8 | 7 | 7
| 2 | 42 | 0.38 | 0 | Trab. ECCE Scleral | NR | None | Yes | None | -5.4 | 8 | 3 | 1 | 28 | 10 | 0 | 0
Robin, 1993 United States Followup: 1 week to 29 days Quality: 76% | 1 | 50 | 0.08 | 0 | Trab. ECCE Scleral Placebo | 0.20 | None | Yes | None | -12.40 | 3 | 4 | 1 | 44 | 2 | 1 | 1
| 2 | 59 | 0.07 | 0 | Trab. ECCE Scleral Apracl-onidine | 0.17 | None | Yes | None | 0.60 | 8 | 8 | 9 | 32 | 10 | 12 | 12
Storr-Paulsen, Pedersen, Laugesen, 1998 Europe Followup: 6 to 11 months Quality: 72% | 1 | 10 | NR | 0 | Trab. Phaco. Scleral | NR | None | Yes | None | NR | NR | NR | NR | 7 | 1 | 0 | 0
| 2 | 10 | NR | 0 | Phaco. Scleral | NR | None | Yes | None | NR | NR | NR | NR | 6 | 3 | 0 | 0
West, Burke, Cunliffe et al., 1992 Europe Followup: ≤23; 24 hours Quality: 69% | 1 | 10 | NR | 0 | ECCE Clear cornea Diamox | 0.00 | None | Yes | None | NR | 3 | 4 | 1 | NR | NR | NR | NR
| 2 | 11 | NR | 0 | ECCE Clear cornea Miochol | 0.00 | Acetyl-choline | Yes | Steroid, Mydriatic | NR | 8 | 1 | 1 | NR | NR | NR | NR
| 3 | 15 | NR | 0 | ECCE Clear cornea Diamox Miochol | 0.00 | Acetyl-choline, Acetazo-lamide | Yes | Steroid, Mydriatic | NR | 5 | 1 | 0 | NR | NR | NR | NR
Study design: Non-randomized controlled trials
Bellucci, Luraschi, 1998 Europe Followup: 6 to 11 months Quality: 24% | 1 | 10 | NR | NR | Trab. Phaco. 1-site | NR | None | No | None | -10.50 | NR | NR | NR | NR | NR | NR | NR
| 2 | 10 | NR | NR | Trab. Phaco. Clear cornea 2-site | NR | None | No | None | -20.6 | NR | NR | NR | NR | NR | NR | NR
Vu, Shields, 1988 United States Followup: 1 to 2 months Quality: 36% | 1 | 25 | 0.04 | 0 | ECCE Scleral | NR | None | No | None | NR | NR | NR | 5 | 12 | NR | NR | NR
| 2 | 25 | 0.12 | 0 | ICCE Scleral | NR | None | No | None | NR | NR | NR | 3 | 8 | NR | NR | NR
Study design: Cohort studies
Derick, Evans, Baker, 1998 United States Followup: 12 to 23 months Quality: 63% | 1 | 42 | 0.11 | NR | Trab. Phaco. Scleral | NR | None | Yes | None | -6.50 | NR | NR | NR | NR | NR | NR | NR
| 2 | 42 | 0.12 | NR | Trab. No CE | NR | None | No | None | -13.00 | NR | NR | NR | NR | NR | NR | NR
Kosmin, Wishart, Ridges, 1997 Europe Followup: 12 to 23 months Quality: 60% | 1 | 30 | NR | NR | Phaco. 1-site Silicone lens | 0.40 | None | Yes | None | -8.70 | NR | NR | NR | NR | NR | NR | NR
| 2 | 30 | NR | NR | Phaco. 1-site PMMA lens | 0.43 | None | Yes | None | -3.40 | NR | NR | NR | NR | NR | NR | NR
Lyle, Jin, 1991 United States Followup: 12 to 23 months Quality: 64% | 1 | 104 | NR | NR | Phaco. 1-site 3mm incision | NR | None | Yes | None | -7.80 | NR | NR | NR | NR | NR | NR | NR
| 2 | 112 | NR | NR | Phaco. 1-site 6mm incision | NR | None | Yes | None | -9.90 | NR | NR | NR | NR | NR | NR | NR
McGuigan, Gottsch, Stark et al., 1986 United States Followup: 12 to 23 months Quality: 40% | 1 | 40 | NR | NR | ECCE Scleral^1^ | NR | None | Yes | None | NR | NR | NR | NR | NR | NR | NR | NR
| 2 | 40 | NR | NR | ECCE Scleral^2^ | NR | None | Yes | None | NR | NR | 2 | 0 | NR | NR | NR | NR
| 3 | 10 | NR | NR | Trab. ECCE Scleral 1-site^3^ | NR | None | Yes | None | NR | NR | NR | NR | NR | NR | NR | NR
McKinzie, Boggs, 1989 United States Followup: ≤ 24 hours Quality: 30% | 1 | 8 | NR | NR | ECCE Scleral | NR | Acetyl-choline | Yes | Beta Blocker, Acetazo-lamide | +16.40 | 1 | 5 | 2 | 0 | 2 | 2 | 2
| 2 | 8 | NR | NR | ECCE Scleral | NR | Carbach ol | Yes | Beta Blocker, Acetazo-lamide | -0.05 | 4 | 0 | 0 | 5 | 3 | 0 | 0
Murchison, Shields, 1990 United States Followup: 12 to 23 months Quality: 67% | 1 | 22 | 0.23 | NR | Trab. Limbus ECCE Scleral | NR | None | Yes | None | NR | 0 | 0 | 0 | NR | NR | NR | NR
| 2 | 25 | 0.12 | NR | Trab Fornix ECCE Scleral | NR | None | Yes | None | NR | NR | NR | NR | NR | NR | NR | NR
Shingleton, Gamell, O'Donoghue et al., 1999 United States Followup: Not Reported Quality: 59% | 1 | 164 | NR | 0 | Phaco. Clear cornea | 0.00 | None | Yes | Pilocar-pine | -0.25 | NR | NR | NR | NR | NR | NR | NR
| 2 | 75 | NR | 0 | Phaco. Clear cornea | 0.01 | None | Yes | Beta Blocker, Pilocar-pine | -1-91 | NR | NR | NR | NR | NR | NR | NR
| 3 | 71 | NR | 0 | Phaco. Clear cornea | 0.07 | None | Yes | Beta Blocker, Pilocar-pine | -1.11 | NR | NR | NR | NR | NR | NR | NR
Tezel, Kolker, Kass et al., 1997a United States Followup: 12 to 23 months Quality: 40% | 1 | 151 | 0.14 | NR | Trab. Limbus Phaco. 1-site | NR | Acetyl-choline | Yes | None | -7.4 | NR | NR | NR | NR | NR | NR | NR
| 2 | 64 | 0.10 | NR | Trab. Fornix Phaco. 1-site | NR | Acetyl-choline | Yes | None | -7.3 | NR | NR | NR | NR | NR | NR | NR

1 Glaucoma patients.

2 Non-glaucoma patients.

3 Glaucoma suspects.

Evidence Table 6. What is the effect of glaucoma surgery on the development and progression of cataract?

| | | | | | | Outcomes/Benefits
Study Information (Author, year; Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Intervention | Antifibrosis Agents? | # Eyes with Significant Cataract | # Eyes with 2 Snellen Line Decrease | # Eyes with Increased Lens Opacity | # Eyes Requiring Cataract Surgery
Study design: Randomized controlled trials
Advanced Glaucoma Intervention Study, The (AGIS):, 1998 United States Followup: ≥24 months Quality: 70% | 1 | 240 | NR | 0 | Trabeculoplasty | None Given | NR | NR | NR | 54
| 2 | 211 | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 73
| 3 | 158 | NR | 0 | Trabeculoplasty | None Given | NR | NR | NR | 47
| 4 | 167 | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 62
Blondeau, Phelps, 1981 United States Followup: ≥24 months Quality: 75% | 1 | 48 | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 0
| 2 | 50 | NR | 0 | Thermosclerostomy | None Given | NR | NR | NR | 10
Collaborative Normal-Tension Glaucoma Study Group, 1998a United States Followup: ≥24 months Quality: 67% | 1 | 61 | 0.08 | 0 | Trabeculoplasty, Trabeculectomy, Cataract extraction, Other medications | MMC, Intraoperative 5-FU, Postoperative 5-FU | 23 | NR | NR | NR
| 2 | 79 | 0.03 | 0 | Cataract extraction | None Given | 11 | NR | NR | NR
Collaborative Normal-Tension Glaucoma Study Group, 1998b United States Followup: ≥24 months Quality: 67% | 1 | 66 | NR | 0 | Trabeculoplasty, Trabeculectomy, Cataract extraction, Antifibrosis agents, Other medications | MMC, Intraoperative 5-FU, Postoperative 5-FU | NR | 23 | NR | NR
| 2 | 79 | NR | 0 | Cataract extraction | None Given | NR | 11 | NR | NR
Demailly, Kretz, 1992 Europe Followup: 6 to 11 months Quality: 35% | 1 | 14 | NR | NR | Trabeculectomy, Antifibrosis agents | Postoperative 5-FU | 3 | NR | NR | NR
| 2 | 13 | NR | NR | Trabeculectomy, Antifibrosis agents | None Given | 3 | NR | NR | NR
Kitazawa, Suemori-Matsushita, Yamamoto et al., 1993 Japan Followup: 6 to 11 months Quality: 73% | 1 | 11 | NR | 0 | Trabeculectomy, Antifibrosis agents | MMC | 2 | 2 | NR | NR
| 2 | 11 | NR | 0 | Trabeculectomy, Antifibrosis agents | MMC | 0 | 0 | NR | NR
Lewis, Phelps, 1984 United States Followup: ≥24 months Quality: 76% | 1 | 37 | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 3
| 2 | 34 | NR | 0 | Thermosclerostomy | None Given | NR | NR | NR | 9
Robin, Ramakrishnan, Krishnadas et al., 1997 India Followup: Not Reported Quality: 78% | 1 | 71 | NR | 0 | Trabeculectomy | None Given | NR | 0 | 18 | 0
| 2 | 78 | NR | 0 | Trabeculectomy, Antifibrosis agents | MMC | NR | 3 | 24 | 3
| 3 | 77 | NR | 0 | Trabeculectomy, Antifibrosis agents | MMC | NR | 1 | 32 | 1
| 4 | 74 | NR | 0 | Trabeculectomy, Antifibrosis agents | MMC | NR | 2 | 23 | 2
Sanders, Cantor, Dobler et al., 1999 United States Followup: 6 to 11 months Quality: 88% | 1 | 25 | 0.16 | NR | Trabeculectomy, Antifibrosis agents | MMC | NR | NR | 4 | 0
| 2 | 25 | 0.08 | NR | Trabeculectomy, Antifibrosis agents | MMC | NR | NR | 3 | 1
Spaeth, 1980 United States Followup: ≥24 months Quality: 22% | 1 | 15 | NR | NR | Trabeculectomy | None Given | NR | NR | 8 | 2
| 2 | 15 | NR | NR | Thermal sclerostomy | None Given | NR | NR | 6 | 1
Wilson, 1989 St. Lucia Followup: ≥24 months Quality: 74% | 1 | 45 | 1.0 | NR | Posterior sclerectomy | None Given | 14 | NR | NR | NR
| 2 | 35 | 1.0 | NR | Trabeculectomy | None Given | 11 | NR | NR | NR
Study design: Non-randomized controlled trials
Dastur, 1994 Bombay, India Followup: ≥24 months Quality: 44% | 1 | 70 | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 12
| 2 | 70 | NR | 0 | Other medications | None Given | NR | NR | NR | 0
Tuulonen, Niva, Alanko, 1987 Europe Followup: ≥24 months Quality: 56% | 1 | 32 | NR | 0 | Trabeculoplasty | None Given | NR | NR | NR | 3
| 2 | 32 | NR | 0 | Other medication | None Given | NR | NR | NR | 3
Study design: Case-control studies
Costa, Smith, Spaeth et al., 1993 United States Followup: 3 to 5 months Quality: Not Applicable | 1 | 16 | 0.12 | NR | Trabeculectomy, Antifibrosis agents | MMC, Intraoperative 5-FU, Postoperative 5-FU | 5 | NR | 16 | 5
| 2 | 68 | 0.12 | NR | Trabeculectomy, Antifibrosis agents | MMC, Intraoperative 5-FU, Postoperative 5-FU | 0 | NR | 0 | 0
Study design: Clinical series
Asamoto, Yablonski, 1993 United States Followup: ≥24 months Quality: Not Applicable | 1 | 98 | 0.15 | NR | Trabeculectomy, Air | None Given | NR | NR | 47 | 20
| 2 | 47 | 0.23 | NR | Trabeculectomy, BSS | None Given | NR | NR | 26 | 14
| 3 | 12 | 0.08 | NR | Trabeculectomy, Healon | None Given | NR | NR | 6 | 2
| 4 | 16 | 0.25 | NR | Trabeculectomy | None Given | NR | NR | 5 | 1
Cheung, Wright, Murali et al., 1997 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 157 | 0.01 | NR | Trabeculectomy, Antifibrosis agents | MMC, Postoperative 5-FU | 7 | 7 | 31 | NR
Jerndal, Lundstrom, 1980 Europe Followup: ≥24 months Quality: Not Applicable | 1 | 281 | NR | NR | Trabeculectomy | None Given | NR | 70 | NR | 29
Karlen, Sanchez, Schnyder et al., 1999 Europe Followup: 12 to 23 months Quality: Not Applicable | 1 | 100 | 0.00 | 0 | Antifibrosis agents, DSCI | MMC, Intraoperative 5-FU, Postoperative 5-FU | NR | NR | 7 | 0
Lamping, Bellows, Hutchinson et al., 1986 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | Can't Tell | NR | 0 | Posterior lip sclerectomy | None Given | NR | NR | NR | 61
| 2 | Can't Tell | NR | 0 | Trabeculectomy | None Given | NR | NR | NR | 15
Tanihara, Negi, Akimoto et al., 1993 Japan Followup: ≥24 months Quality: Not Applicable | 1 | 439 | NR | 0 | Trabeculectomy | None Given | NR | 9 | NR | NR
Tornqvist, Drolsum, 1991 Europe Followup: Not Reported Quality: Not Applicable | 1 | 277 | NR | 0 | Trabeculectomy | None Given | 60 | 60 | NR | NR
Watson, Jakeman, Ozturk et al., 1990 Europe Followup: ≥24 months Quality: Not Applicable | 1 | 150 | NR | NR | Trabeculectomy | None Given | NR | NR | 20 | 8

Evidence Table 7. What is the effect of mitomycin-C on intraocular pressure control after combined cataract and glaucoma surgery?

| | | | | | | Outcomes/Benefits
Study Information (Author, Year; Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Mitomycin (Concentration, Duration) | Cataract Surgery (Technique, Incision) | Mean IOP Change | # Eyes with 30% Reduction IOP | # Eyes with IOP ≤ 21mm Hg | # Achieving Target IOP | Mean # of Medications | # Eyes Needing Medications
Study design: Randomized controlled trials
Carlson, Alward, Barad et al., 1997 United States Followup: 12 to 23 months Quality: 79% | 1 | 14 | 0.00 | 0 | 0.5 mg/ml 3-3.9 minutes | Phaco. 1-site | -5.80 | NR | NR | NR | NR | 0
| 2 | 15 | 0.06 | 0 | Placebo | Phaco. 1-site | -2.90 | NR | NR | NR | NR | 5
Cohen, Greff, Novack et al., 1996 United States Followup: 12 to 23 months Quality: 69% | 1 | 36 | 0.19 | 0 | 0.5 mg/ml 2-2.9 minutes | Phaco. Scleral 1-site | -7.70 | NR | NR | NR | 0.60 | NR
| 2 | 35 | 0.17 | 0 | Placebo | Phaco. Scleral 1-site | -3.1 | NR | NR | NR | 1.4 | NR
Lemon, Shin, Kim et al., 1998 United States Followup: Not Reported Quality: 66% | 1 | 30 | 0.70 | 0 | 0.5 mg/ml 1-1.9 minute | Phaco. 1-site | -3.30 | NR | NR | NR | 1.40 | NR
| 2 | 39 | 0.56 | 0 | 0.5 mg/ml 1-1.9 minute | Phaco. 1-site | -3.40 | NR | NR | NR | 1.30 | NR
Shin, Kim, Sheth et al., 1998 United States Followup: ≥ 24 months Quality: 53% | 1 | 21 | 0.81 | NR | 0.5 mg/ml 1-1.9 minute | Phaco. | NR | NR | NR | NR | NR | NR
| 2 | 28 | 0.50 | NR | None given | Phaco. 1-site | NR | NR | NR | NR | NR | NR
Shin, Ren, Juzych et al., 1998 United States Followup: ≥ 24 months Quality: 78% | 1 | NR | NR | 0 | None given | Phaco. 1-site | NR | NR | NR | NR | NR | NR
| 2 | NR | NR | 0 | 0.5 mg/ml Can't Tell | Phaco. 1-site | NR | NR | NR | NR | NR | NR
Shin, Kim, Ren et al., 1998 United States Followup: ≥ 24 months Quality: 78% | 1 | 81 | 0.53 | 0 | 0.5 mg/ml Can't Tell | Phaco. Scleral 1-site | NR | NR | NR | NR | NR | NR
| 2 | 93 | 0.46 | 0 | None given | Phaco. Scleral 1-site | NR | NR | NR | NR | NR | NR
Study design: Cohort studies
Budenz, Pyfer, Singh et al., 1999 United States Followup: 12 to 23 months Quality: 58% | 1 | 21 | 0.38 | 0 | None given | Phaco. 1-site | -3.4 | NR | NR | NR | 0.7 | NR
| 2 | 28 | 0.46 | 0 | None given | Phaco. 1-site | -3.7 | NR | NR | NR | 1.1 | NR
| 3 | 29 | 0.28 | NR | Can't Tell Can't Tell | Phaco. 1-site | -4.60 | NR | NR | NR | 0.40 | NR
Liu, Su, Chou et al., 2000 Taiwan Followup: 12 to 23 months Quality: 63% | 1 | 22 | NR | 0 | 0.2 mg/ml 3-3.9 minutes | Phaco. 1-site | -5.16 | NR | NR | NR | 0.18 | NR
| 2 | 18 | NR | 0 | None given | Phaco. 1-site | -4.12 | NR | NR | NR | 0.72 | NR
Study design: Case-control studies
El-Sayyad, Helal, Khalil et al., 1999 Saudi Arabia Followup: Not Reported Quality: Not Applicable | 1 | 53 | 0.25 | 0 | 0.3 mg/ml 4-4.9 minutes | Phaco. Scleral Clear cornea | -13.80 | NR | 96 | NR | NR | 5
| 2 | 53 | 0.23 | 0 | 0.3 mg/ml 4-4.9 minutes | Phaco. Scleral 1-site | -14.70 | NR | 60 | NR | NR | 2

Evidence Table 8. What is the effect of 5-fluorouracil on intraocular pressure control after combined cataract and glaucoma surgery?

| | | | | | | | Outcomes/Benefits
Study Information (Author, Year; Locations; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior | Intraoperative 5-Flurorouracil (concentration, duration) | Postoperative 5-Flurouracil (Dose,# of Injections) | Cataract Surgery (Technique, Incision) | Mean IOP Change | # Eyes with 30% Reduction IOP | # Eyes with IOP ≤ 21mm Hg | # Achieving Target IOP | Mean # of Medications | # Eyes Needing Medications
Study design: Randomized controlled trials.
Gandolfi, Vecchi, 1997 Europe Followup: Not Reported Quality: 62% | 1 | 12 | NR | 0 | NR | NR | Phaco. Clear cornea 2-site | -7.30 | NR | NR | NR | 0 | NR
| 2 | 12 | NR | 0 | NR | 25mg, 5 | Phaco. Clear cornea 2-site | -13.60 | NR | NR | NR | 0.00 | NR
Hennis, Stewart, 1991 United States Followup: Not Reported Quality: 50% | 1 | 15 | 0.67 | NR | NR | 5mg, 14 | ECCE 1-site | -3.00 | NR | NR | NR | 0.90 | 8
| 2 | 2 | 0.88 | NR | NR | NR | ECCE 1-site | -2.60 | NR | NR | NR | 0.7 | 9
O'Grady, Juzych, Shin et al., 1993 United States Followup: Not Reported Quality: 45% | 1 | NR | NR | NR | Injection 5mg | Can't Tell Can't Tell | Phaco. Scleral 1-site | -4.10 | NR | NR | NR | 0.70 | NR
| 2 | NR | NR | 16 | NR | NR | Phaco. Scleral 1-site | -3.00 | NR | NR | NR | 0.7 | NR
Wong, Ruderman, Krupin et al., 1994 United States Followup: Not Reported Quality: 62% | 1 | 24 | 0.04 | NR | NR | 5mg, 5 | ECCE Scleral Can't Tell | -4.40 | NR | 24 | NR | 0.80 | 14
| 2 | 20 | 0.15 | NR | NR | NR | ECCE Scleral Can't Tell | -3.90 | NR | 20 | NR | 1 | 12
Study design: Cohort studies
Budenz, Pyfer, Singh et al., 1999 United States Followup: Not Reported Quality: 58% | 1 | 21 | 0.38 | NR | NR | NR | Phaco. 1-site | -3.40 | NR | NR | NR | 0.70 | NR
| 2 | 28 | 0.46 | NR | 50mg/ml 5 minutes | 5mg, Can't Tell | Phaco. 1-site | -3.70 | NR | NR | NR | 1.10 | NR
| 3 | 29 | 0.28 | NR | NR | 5mg, Can't Tell | Phaco. 1-site | -4.60 | NR | NR | NR | 0.40 | NR
Cohen, 1990 United States Followup: Not Reported Quality: 61% | 1 | 22 | 0.05 | NR | NR | NR | Can't Tell Scleral | -4.50 | NR | 19 | 19 | NR | 17
| 2 | 22 | 0.23 | NR | Injection 5mg | 5mg, Can't Tell | Can't Tell Scleral | -4.10 | NR | 21 | 21 | NR | 10
Hurvitz, 1993 United States Followup: Not Reported Quality:33% | 1 | NR | NR | NR | NR | NR | ECCE Scleral 1-site | -3.40 | NR | NR | NR | 1.21 | NR
| 2 | NR | NR | NR | NR | NR | Phaco. Scleral 1-site | -5.30 | NR | NR | NR | 1.02 | NR
| 3 | NR | NR | NR | NR | Can't Tell Can't Tell | Phaco. Scleral 1-site | -6.20 | NR | NR | NR | 0.50 | NR
Study design: Case-control studies
Donoso, Rodriguez, 2000 Chile Followup: Not Reported Quality: Not Applicable | | 1 | 18 | NR | NR | 50mg/ml Can't Tell | NR | Phaco. Scleral | 1.80 | NR | 18 | NR | 0.00 | 0
| 2 | 22 | NR | NR | 50mg/ml Can't Tell | NR | Phaco. Scleral 1-site | -7.60 | NR | 22 | NR | 0.00 | 0

Evidence Table 9. Which cataract or combined procedure techniques lower intraocular pressure the most?

| | | | | | | Outcomes/Benefits
Study Information (Author, Year; Location; Mean Folowup; Quality Score | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Cataract Surgery (Technique, Incision) | Proportion of Eyes with Pupil Manipulation | Mean IOP Change | # Eyes with 30% Reduction IOP | # Eyes with IOP ≤21mm Hg | # Achieving Target IOP | Mean # of Medications | # Eyes Needing Medications
Study design: Randomized controlled trials
Borggrefe, Lieb, Grehn, 1999 Europe Followup: 12 to 23 months Quality: 64% | 1 | 25 | NR | 0 | Phaco. Scleral | NR | -12.70 | 21 | 23 | NR | NR | 7
| 2 | 25 | NR | 0 | Phaco. 2-site | NR | -15.12 | 23 | 24 | NR | NR | 8
El-Sayyad, Helal, El-Maghraby et al., 1999 Saudi Arabia Followup: Not Reported Quality: 61% | 1 | 39 | NR | NR | Phaco. Clear cornea 2-site | NR | -11.00 | NR | 34 | NR | 1.90 | NR
| 2 | 37 | NR | NR | Phaco. 1-site | NR | -7.10 | NR | 29 | NR | 1.60 | NR
Rossetti, Bucci, Miglior et al., 1997 Europe Followup: Not Reported Quality: 11% | 1 | 25 | NR | NR | Phaco. 1-site | NR | -9.40 | NR | NR | NR | 0.32 | NR
| 2 | 25 | NR | NR | Phaco. Clear cornea | NR | -11.00 | NR | NR | NR | 0.16 | NR
Wyse, Meyer, Ruderman et al., 1998 United States Followup: 12 to 23 months Quality: 60% | 1 | 20 | NR | 0 | Phaco. 1-site | NR | -5.20 | NR | NR | NR | 0.80 | 11
| 2 | 13 | NR | 0 | Phaco. 2-site | NR | -6.60 | NR | NR | NR | 0.20 | 2
Study design: Non-randomized controlled trials
Bellucci, Luraschi, 1998 Europe Followup: 6 to 11 months Quality: 24% | 1 | 10 | NR | NR | Phaco. 1-site | NR | -5.80 | NR | NR | NR | NR | NR
| 2 | 10 | NR | NR | Phaco. Cornea 2-site | NR | -9.50 | NR | NR | NR | NR | NR
Study design: Cohort studies
Anand, Menage, Bailey, 1997 Europe Followup: 6 to 11 months Quality: 28% | 1 | 35 | 0 | NR | ECCE Scleral 1-site | NR | -8.10 | NR | 32 | NR | 0.30 | 8
| 2 | 54 | 0 | NR | ECCE Scleral 2-site | NR | -9.90 | NR | 46 | NR | 0.50 | 18
| 3 | 43 | 0 | NR | Phaco. Scleral 1-site | NR | -10.60 | NR | 42 | NR | 0.20 | 9
Chia, Goldberg, 1998 Australia Followup: 12 to 23 months Quality: 50% | 1 | 50 | NR | NR | ECCE 1-site | NR | -2.50 | NR | NR | NR | NR | NR
| 2 | 50 | NR | NR | Phaco. 1-site | NR | -5.80 | NR | NR | NR | NR | NR
Gayton, Van der Karr, Sanders, 1996 United States Followup: 12 to 23 months Quality: 31% | 1 | 50 | NR | NR | Phaco. Scleral 1-site | NR | NR | NR | NR | NR | NR | 8
| 2 | 65 | NR | NR | Phaco. Scleral 2-site | NR | NR | NR | NR | NR | NR | 3
Hurvitz, 1993 United States Followup: 12 to 23 months Quality: 33% | 1 | NR | 0.03 | NR | ECCE Scleral 1-site | NR | -3.40 | NR | NR | NR | 1.21 | NR
| 2 | NR | 0.02 | NR | Phaco. Scleral 1-site | NR | -5.30 | NR | NR | NR | 1.02 | NR
| 3 | NR | 0.08 | NR | Phaco. Scleral 1-site | NR | -6.20 | NR | NR | NR | 0.50 | NR
Honjo, Tanihara, Negi et al., 1996 Japan Followup: Not Reported Quality: 13% | 1 | 25 | NR | NR | ECCE Scleral 1-site | NR | -9.60 | NR | 15 | NR | 1.10 | NR
| 2 | 10 | NR | NR | Phaco. Scleral 2-site | NR | -7.40 | NR | 6 | NR | 0.60 | NR
| 3 | 12 | NR | NR | Phaco. Scleral 1-site | NR | -11.60 | NR | 6 | NR | 1.40 | NR
Kosmin, Wishart, Ridges, 1998 Europe Followup: ≥ 24 months Quality: 50% | 1 | 32 | NR | NR | ECCE Scleral Clear cornea 1-site 2-site | NR | -6.66 | NR | NR | NR | 0.94 | 18
| 2 | 31 | NR | NR | Phaco. Scleral 1-site | NR | -4.68 | NR | NR | NR | 0.58 | 13
Manoj, Chako, Khan, 2000 Europe Followup: ≥ 24 months Quality: 33% | 1 | 34 | NR | NR | ECCE Clear cornea | NR | 0.28 | NR | 33 | NR | NR | 7
| 2 | 21 | NR | NR | Phaco. Clear cornea | NR | -0.56 | NR | 21 | NR | NR | 0
Shingleton, Jacobson, Kuperwaser, 1995 United States Followup: 12 to 23 months Quality: 46% | 1 | 35 | NR | NR | ECCE Scleral 1-site | NR | -3.20 | NR | NR | NR | 0.50 | NR
| 2 | 37 | NR | NR | Phaco. Scleral 1-site | NR | -5.40 | NR | NR | NR | 0.40 | NR
Stewart, Crinkley, Carlson, 1994b United States Followup: 6 to 11 months Quality: 36% | 1 | NR | 0.50 | NR | Phaco. Scleral 2-site | NR | -3.80 | NR | NR | NR | 0.79 | 7
| 2 | NR | 0.67 | NR | ECCE Scleral 2-site | NR | -2.90 | NR | NR | NR | 1.40 | 14
Tezel, Kolker, Kass et al., 1997a United States Followup: 12 to 23 months Quality: 48% | 1 | 127 | 0.13 | NR | ECCE 1-site | NR | -7.70 | NR | 30 | NR | 1.90 | 97
| 2 | 270 | 0.13 | NR | Phaco. 1-site | NR | -5.70 | NR | 147 | NR | 0.70 | 123
Wedrich, Menapace, Hirsch et al., 1996 Europe Followup: ≥ 24 months Quality: 43% | 1 | NR | NR | NR | ECCE 1-site | NR | -5.50 | NR | NR | NR | NR | NR
| 2 | NR | NR | NR | Phaco. 1-site | NR | -7.80 | NR | NR | NR | NR | NR
Wishart, Austin, 1993 Europe Followup: 12 to 23 months Quality: 54% | 1 | 34 | NR | NR | ECCE Scleral 1-site | NR | -8.60 | NR | NR | NR | 1.20 | NR
| 2 | 34 | NR | NR | Phaco. Scleral 1-site | NR | -5.20 | NR | NR | NR | 1.00 | NR

Evidence Table 10. Is intraocular pressure lowered more by a staged glaucoma and cataract surgery or by simultaneous cataract and glaucoma surgery?

| | | | | | | Outcomes/Benefits
Study Information (Author, Year; Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Cataract Surgery (Technique, Incision) | Proportion of Eyes Requiring Pupil Manipulation | Mean IOP Change | # Eyes with 30% Reduction IOP | # Eyes with IOP ≤ 21mm Hg | # Achieving Target IOP | Mean # of Medications | # Eyes Needing Medications
Study design: Cohort Studies
Murchison, Shields, 1989 United States Followup: 12 to 23 months Quality: 44% | 1 | 34 | NR | NR | ECCE Scleral | NR | -2.20 | NR | NR | NR | NR | NR
| 2 | 22 | NR | NR | ECCE Scleral | NR | -1.70 | NR | NR | NR | NR | NR
| 3 | 22 | NR | NR | ECCE Clear cornea | NR | -11.69 | NR | NR | NR | NR | NR
Study design: Case-control studies
Caprioli, Park, Kwon et al., 1997 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | 40 | 0.10 | NR | Phaco. Clear Cornea | 0.18 | -0.20 | NR | NR | NR | 0.6 | NR
| 2 | 40 | 0.05 | NR | No CE | NR | 0.3 | NR | NR | NR | 0.7 | NR
Donoso, Rodriguez, 2000 Chile Followup: 12 to 23 months Quality: Not Applicable | 1 | 18 | NR | NR | Phaco. Scleral | NR | 1.80 | NR | 18 | NR | 0 | 0
| 2 | 22 | NR | NR | Phaco. Scleral 1-site | NR | -7.59 | NR | 22 | NR | NR | NR
El-Sayyad, Helal, Khalil et al., 1999 Saudi Arabia Followup: Not Reported Quality: Not Applicable | 1 | 53 | 0.25 | 0 | Phaco. Scleral Clear cornea | NR | -13.79 | NR | 96 | NR | NR | 5
| 2 | 53 | 0.23 | 0 | Phaco. Scleral | NR | -14.70 | NR | 60 | NR | NR | 2

Evidence Table 11. Does trabeculectomy combined with cataract surgery or another operation combined with cataract surgery lower intraocular pressure more?

| | | | | | | | | | Outcome/Benefits
Study Information (Author, Year; Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | Proportion of Patients African-American | Mean Number of Prior Conjunctival Surgeries | Trabeculectomy (Incision Location) | Endoscopic Laser (Angle, Power) | Cataract Surgery (Technique, Incision) | Percentage of Eyes | Number of Eyes at Reported Followup | Mean IOP Change | # Eyes with | # Eyes with | # Achieving | Mean # of Medications | # Eyes Needing Medications
Study design: Randomized controlled trials
Gayton, Van der Karr, Sanders, 1999 United States Followup: Not Reported Quality: 50% | 1 | 29 | 0.48 | NR | NR | Angle: Power: Can't Tell | Phaco. Clear cornea 1-site | NR | 16 | -7.30 | NR | NR | NR | 1.40 | 15
| 2 | 29 | 0.31 | NR | Can't Tell | | Phaco. 2-site | NR | 13 | -10.60 | NR | NR | NR | 0.07 | 7
Gianoli, Schnyder, Bovey et al., 1999 Europe Followup: 12 to 23 months Quality: 59% | 1 | 30 | NR | 0 | NR | | Phaco. Clear cornea 2-site | NR | NR | -10.9 | NR | NR | NR | 0.6 | NR
| 2 | 30 | NR | 0 | Can't Tell | | Phaco. Scleral 1-site | NR | NR | -9.9 | NR | NR | NR | 0.6 | NR
Study design: Cohort studies
Kendrick, Kollarits, Khan, 1996 United States Followup: Not Reported Quality: 20% | 1 | 51 | NR | NR | NR | | Phaco. Scleral | NR | 51 | -5.20 | NR | NR | NR | 0.60 | 10
| 2 | 19 | NR | NR | Limbus | | Phaco. Scleral | NR | 19 | -2.30 | NR | NR | NR | 0.40 | 5

Evidence Table 12. Complications of treatment for coexisting glaucoma and cataract

| | | | Complications (Number of Eyes)
| | | | Early | | | | | | | | | | Late
Study Information (Author, Year; Location; Mean Followup; Quality Score) | Study Group | Number of Eyes Enrolled | No Complications Observed | PC Rupture | Bleb Leak | Choroidal | Endophthalmitis | Epi. Defect | Fibrinous Reaction | Hyphema | Hyphotony | Suprachoroidal Hem. | Vitreous Hem. | Tenon's Cyst | Bleb Leak | CME | Endophthalmitis (Late) | Graft Failure | Hypotony Maculopathy | Wound Leak | PCO
Study design: Randomized controlled trials
Anders, Pham, Holschbach et al., 1997 Europe Followup: 12 to 23 months Quality: 67% | 1 | 43 | | | | 0 | | | | 2 | 0 | | | 1
| 2 | 42
Blondeau, Phelps, 1981 United States Followup: ≥ 24 months Quality: 75% | 1 | 48 | | | | 0 | | | | 4 | 5 | | | | | | | | | 3
| 2 | 50 | | | | 1 | | | | 8 | 10 | | | | | | | | | 3
Bobrow, 1998 United States Followup: ≥ 24 months Quality: 82% | 1 | 35 | | 1 | | 1 | | | | 3 | 1 | | | | | 1 | | | | | 6
| 2 | 35 | | 1 | | 0 | | | | 0 | 0 | | | | | 0 | | | | | 9
Borggrefe, Lieb, Grehn, 1999 Europe Followup: 12 to 23 months Quality: 64% | 1 | 25 | | 1 | | 4 | | | 6 | 3 | 4
| 2 | 25 | | 1 | | 3 | | | 6 | 4 | 1
Carlson, Alward, Barad et al., 1997 United States Followup: 12 to 23 months Quality: 79% | 1 | 14 | | 0 | | 3 | | | 1 | 1 | | | | 2 | | | 1 | | 0 | 0 | 3
| 2 | 15 | | 1 | | 4 | | | 0 | 1 | | | | 3 | | | 0 | | 1 | 1 | 4
Cohen, Greff, Novack et al., 1996 United States Followup: 12 to 23 months Quality: 69% | 1 | 36 | | | | | | | 7 | | 2 | | | | | | | | | 1
| 2 | 35 | | | | | | | 5 | | 0 | | | | | | | | | 0
Collaborative Normal-Tension Glaucoma Study Group, 1998a United States Followup: ≥ 24 months Quality: 67% | 1 | 61 | √
| 2 | 79 | √
Collaborative Normal-Tension Glaucoma Study Group, 1998b United States Followup: ≥ 24 months Quality: 67% | 1 | 66 | √
| 2 | 79 | √
Demailly, Kretz, 1992 Europe Followup: 6 to 11 months Quality: 35% | 1 | 14 | | | | 6 | | 3
| 2 | 13 | | | | 2 | | 2
El-Sayyad, Helal, El-Maghraby et al., 1999 Saudi Arabia Followup: Not Reported Quality: 61% | 1 | 39 | | 1 | 1 | 2 | 0 | | | 3 | | | | | | | 0 | | 0 | 0 | 6
| 2 | 37 | | 3 | 3 | 1 | 0 | | | 5 | | | | | | | 0 | | 1 | 1 | 8
Gandolfi, Vecchi, 1997 Europe Followup: 12 to 23 months Quality: 62% | 1 | 12 | | | | 3 | | | | 0 | 0 | 0 | | | | | | | 0 | 0
| 2 | 12 | | | | 2 | | | | 0 | 0 | 0 | | | | | | | 0 | 0
Gayton, Van Der Karr, Sanders, 1999 United States Followup: Not Reported Quality: 50% | 1 | 29 | | | | | | | | 0 | | | | | | | | | | | 1
| 2 | 29 | | | | | | | | 17 | | | | | | | | | | | 0
Gimbel, Meyer, DeBroff et al., 1995 Canada Followup: 12 to 23 months Quality: 63% | 1 | 53 | | | | | | | | 1
| 2 | 53 | | | | | | | | 0
Hennis, Stewart, 1991 United States Followup: 3 to 5 months Quality: 50% | 1 | 15 | | | | 1 | | 1 | 1 | | 1
| 2 | 17 | | | | | | | 2
Hugkulstone, Sadiq, Rubasingham, 1997 Europe Followup: ≥ 24 months Quality: 56% | 1 | 9 | | | | | | | | | | | | | | | | | | | 4
| 2 | 10 | | | | | | | | | | | | | | | | | | | 4
Kitazawa, Suemori-Matsushita, Yamamoto et al., 1993 Japan Followup: 6 to 11 months Quality: 73% | 1 | 11 | | | | 4 | | 2 | | 2 | 2 | | | | | | | | 2 | 0
| 2 | 11 | | | | 3 | | 1 | | 3 | 0 | | | | | | | | 0 | 0
Krupin, Feitl, Bishop, 1989 United States Followup: ≤ 24 hours Quality: 54% | 1 | 26 | | 0 | | | 0 | | | 1 | | | | | | | 0
| 2 | 42 | | 0 | | | 0 | | | 2 | | | | | | | 0
Lemon, Shin, Kim et al., 1998 United States Followup: Not Reported Quality: 66% | 1 | 30 | | | | 3 | | | | 2 | 9 | | | | | 0
| 2 | 39 | | | | 2 | | | | 1 | 3 | | | | | 1
Lewis, Phelps, 1984 United States Followup: ≥ 24 months Quality: 76% | 1 | 37 | | | | | | | | | 5 | | | | | | | | | 3
| 2 | 34 | | | | | | | | | 11 | | | | | | | | | 6
O'Grady, Juzych, Shin et al., 1993 United States Followup: 12 to 23 months Quality: 45% | 1 | N.R. | | | | 2 | | 10
| 2 | N.R. | | | | 1 | | 0
Robin, Ramakrishnan, Krishnadas et al., 1997 India Followup: Not Reported Quality: 78% | 1 | 71 | | | | 0 | | | | | | 0 | | | 0 | | 0
| 2 | 78 | | | | 0 | | | | | | 0 | | | 1 | | 0 | | 2
| 3 | 77 | | | | 3 | | | | | | 0 | | | 0 | | 0 | | 2
| 4 | 74 | | | | 0 | | | | | | 0 | | | 0 | | 0 | | 2
Sanders, Cantor, Dobler et al., 1999 United States Followup: 6 to 11 months Quality: 88% | 1 | 25 | | | 2 | 1 | | | 0 | 2 | 2 | 1 | 2 | 1 | | | 0 | | 0
| 2 | 25 | | | 2 | 0 | | | 1 | 5 | 3 | 2 | 1 | | | | 1 | | 1
Shin, Kim, Ren et al., 1998 United States Followup: ≥ 24; months Quality: 78% | 1 | 81 | | | | | 1
| 2 | 93
Spaeth, 1980 United States Followup: ≥ 24 months Quality: 22% | 1 | 15 | | | | | | | | 5
| 2 | 15 | | | | | | | | 4
Storr-Paulsen, Pedersen, Laugesen, 1998 Europe Followup: 6 to 11 months Quality: 72% | 1 | 10 | | | | | | | | | 0
| 2 | 10 | | | | | | | | | 0
West, Burke, Cunliffe et al., 1992 Europe Followup: ≤ 24 hours Quality: 69% | 1 | 10
| 2 | 11
| 3 | 15
Wilson, 1989 St. Lucia Followup: ≥ 24 months Quality: 74% | 1 | 45 | | 1 | | 2 | | | | | | 1
| 2 | 35 | | 0 | | 2 | | | | | | 0
Wong, Ruderman, Krupin et al., 1994 United States Followup: 12 to 23 months Quality: 62% | 1 | 24 | | | 2 | 4 | | 16 | | 12
| 2 | 20 | | | 5 | 4 | | 7 | | 8
Study design: Non-randomized controlled trials
Bellucci, Luraschi, 1998 Europe Followup: 6 to 11 months Quality: 24% | 1 | 10
| 2 | 10
Nielsen, 1997 Europe Followup: 12 to 23 months Quality: 29% | 1 | 10 | | | | 1 | | | | 2 | 0 | | 0 | | | | | | | | 1
| 2 | 16 | | | | 1 | | | | 8 | 3 | | 1 | | | | | | | | 1
Shingleton, Chaudhry, O'Donoghue et al., 1999 United States Followup: Not Reported Quality: 63% | 1 | 44 | | 0 | 0 | 1 | 0 | | 0 | 2 | | 1 | 1 | 1 | 0 | 1 | 0 | | | 0 | 7
| 2 | 44 | | 0 | 1 | 4 | 0 | | 1 | 2 | | 0 | 0 | 0 | 1 | 1 | 0 | | | 1 | 7
Vyas, Bacon, Percival, 1998 Europe Followup: 12 to 23 months Quality: 34% | 1 | 25 | | | | 0 | | | 3 | 2
| 2 | 25 | | | | 2 | | | 5 | 5
Study design: Cohort studies
Anand, Menage, Bailey, 1997 Europe Followup: 6 to 11 months Quality: 28% | 1 | 35 | | 3 | | | | | 6 | 16 | | | | | | | | | | 1 | 7
| 2 | 54 | | 1 | | | | | 12 | 12 | | | | | | | | | | 4 | 11
| 3 | 43 | | 1 | | | | | 5 | 12 | | | | | | | | | | 0 | 2
Arnold, 1996 United States Followup: Not Reported Quality: 37% | 1 | 20 | | | | 1 | | | 5 | 12
| 2 | 20 | | | | 2 | | | 3 | 11
Bellucci, Perfetti, Babighian et al., 1997 Europe Followup: Not Reported Quality: 21% | 1 | 100 | | | | 17
| 2 | 200 | | 5 | | 12
Berestka, Brown, 1997 United States Followup: Not Reported Quality: 48% | 1 | 28 | | 5 | | 6 | 0 | | | 0 | | | | | | 1 | 0 | | 0 | | 7
| 2 | 24 | | 0 | | 8 | 0 | | | 0 | | | | | | 0 | 0 | | 0 | | 1
Budenz, Pyfer, Singh et al., 1999 United States Followup: 12 to 23 months Quality: 58% | 1 | 21 | | 0 | | | | 0 | | 3 | 0 | | | | 0 | 0 | | | 0 | 0
| 2 | 28 | | 1 | | | | 0 | | 2 | 4 | | | | 0 | 2 | | | 0 | 0
| 3 | 29 | | 2 | | | | 1 | | 0 | 3 | | | | 0 | 0 | | | 1 | 0
Caprioli, Park, Weitzman, 1996 United States Followup: 12 to 23 months Quality: 83% | 1 | 40 | | 5 | | | | 1 | | 2
| 2 | 40 | | 0 | | | | 0 | | 7
Chia, Goldberg, 1998 Australia Followup: 12 to 23 months Quality: 50% | 1 | 50 | | | 22 | | | 28 | 18 | 10 | | | 0 | | | | | | | | 30
| 2 | 50 | | | 12 | | | 16 | 8 | 16 | | | 4 | | | | | | | | 20
Cohen, 1990 United States Followup: 6 to 11 months Quality: 61% | 1 | 22 | | 1 | 5 | | | 0 | | 2
| 2 | 22 | | | 13 | | | 0 | | 2
Derick, Evans, Baker, 1998 United States Followup: 12 to 23 months Quality: 63% | 1 | 42 | | 1 | | 2 | | | | 3 | 0 | 1 | 0 | | | 1
| 2 | 42 | | | | 4 | | | | 4 | 2 | | 1
Honjo, Tanihara, Negi et al., 1996 Japan Followup: Not Reported Quality: 13% | 1 | 25 | | 1 | | | 0 | | 15 | 3 | | 1 | | | | | 0
| 2 | 10 | | 0 | | | 0 | | 0 | 1 | | 0 | | | | | 0
| 3 | 12 | | 1 | | | 0 | | 2 | 1 | | 0 | | | | | 0
Hurvitz, 1993 United States Followup: 12 to 23 months Quality: 33% | 1 | N.R. | | | | | 0 | | | | | 0 | | | | 0 | 0
| 2 | N.R. | | | | | 0 | | | | | 0 | | | | 2 | 0
| 3 | N.R. | | | | | 0 | | | | | 0 | | | | 1 | 0
Kosmin, Wishart, Ridges, 1997 Europe Followup: 12 to 23 months Quality: 50% | 1 | 30 | | | | 5 | | | 8 | 1 | | | | | | | | | | | 2
| 2 | 30 | | | | 1 | | | 3 | 1 | | | | | | | | | | | 3
Liu, Su, Chou et al., 2000 Taiwan Followup: 12 to 23 months Quality: 63% | 1 | 22 | | | | 1 | 0 | | | 1 | | | | | | | 0
| 2 | 18 | | | | 0 | 0 | | | 3 | | | | | | | 0
Lyle, Jin, 1991 United States Followup: 12 to 23 months Quality: 64% | 1 | 104 | | | | 3 | | | | 15 | 3 | | | | | 1 | | | | | 10
| 2 | 112 | | | | 13 | | | | 30 | 15 | | | | | 4 | | | | | 20
McGuigan, Gottsch, Stark et al., 1986 United States Followup: 12 to 23 months Quality: 40% | 1 | 40 | | | | | | 1 | 1 | | | | | | | | | | | | 8
| 2 | 40 | | | | | | | | 3 | | | | | | | | | | | 0
| 3 | 10 | | | | | | | | 4 | | | | | | | | | | | 0
McKinzie, Boggs, 1989 United States Followup: ≤24 hours Quality: 30% | 1 | 8
| 2 | 8
Murchison, Shields, 1989 United States Followup: 12 to 23 months Quality: 44% | 1 | 34
| 2 | 22
| 3 | 22 | | | | 2
Murchison, Shields, 1990 United States Followup: 12 to 23 months Quality: 67% | 1 | 22 | | 4 | | | | | | 8 | | | | | | | | | | | 4
| 2 | 25 | | 0 | | | | | | 5 | | | | | | | | | | | 4
Neumann, Zalish, Oliver, 1988 Israel Followup: 6 to 11 months Quality: 34% | 1 | 23 | | | | | | | 11
| 2 | 23 | | | | | | | 5
Park, Weitzman, Caprioli, 1997 United States Followup: 12 to 23 months Quality: 63% | 1 | 40 | | 5 | | | | | | 2
| 2 | 40 | | | | | | | | 7
Savage, Thomas, Belcher et al., 1985 United States Followup: Not Reported Quality: 29% | 1 | 127 | | 3 | | | | | | 6 | | | | | | 2 | | | | | 9
| 2 | 157 | | 4 | | | | | | 0 | | | | | | 3 | | | | | 8
| 3 | 12
Shingleton, Jacobson, Kuperwaser, 1995 United States Followup: 12 to 23 months Quality: 46% | 1 | 35 | | | | | | | | 0 | | | | | | | | | | 0
| 2 | 37 | | | | | | | | 0 | | | | | | | | | | 0
Shingleton, Gamell, O'Donoghue et al., 1999 United States Followup: Not Reported Quality: 59% | 1 | 164 | | 0 | | 1 | | | 0 | | | 0 | | | | 1 | | | | | 29
| 2 | 75 | | 1 | | 1 | | | 0 | | | 0 | | | | 1 | | | | | 15
| 3 | 71 | | 0 | | 1 | | | 1 | | | 1 | | | | 1 | | | | | 25
Stewart, Crinkley, Carlson, 1994 United States Followup: 6 to 11 months Quality: 36% | 1 | N.R. | | | | 1 | | 0
| 2 | N.R. | | | | 2 | | 1
Tezel, Kolker, Kass et al., 1997a. United States Followup: 12 to 23 months Quality: 40% | 1 | 151 | | | 1 | 19 | | 4 | | 9 | | 0 | 3 | | | | | | 6 | 0 | 38
| 2 | 64 | | | 5 | 8 | | 0 | | 3 | | 1 | 0 | | | | | | 2 | 1 | 9
Tezel, Kolker, Kass et al., 1997b. United States Followup: 12 to 23 months Quality: 48% | 1 | 127 | | | | 12 | | 3 | | 10 | | 2 | 4 | | | | | | 12 | | 50
| 2 | 270 | | | | 32 | | 6 | | 13 | | 3 | 4 | | | | | | 11 | | 58
Wand, 1996 United States Followup: 6 to 11 months Quality: 57% | 1 | 24 | | | | 1 | 1 | | | 1
| 2 | 33 | | | | 0 | 0 | | | 11
Wedrich, Menapace, Hirsch et al., 1996 Europe Followup: ≥ 24 months Quality: 43% | 1 | N.R. | | | | 2 | | | 22 | 12
| 2 | N.R. | | | | 1 | | | 9 | 18
Wishart, Austin, 1993 Europe Followup: 12 to 23 months Quality: 54% | 1 | 34 | | 0 | | 6 | | | 11 | 13 | 12 | | | | | | | | | | 8
| 2 | 34 | | 0 | | 1 | | | 2 | 1 | 5 | | | | | | | | | | 1
Yalvac, Airaksinen, Tuulonen, 1997 Europe Followup: Not Reported Quality: 46% | 1 | 35 | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| 2 | 21 | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Yu, Chong, Caesar et al., 1996 Europe Followup: 12 to 23 months Quality: 65% | 1 | 21 | | | | | | | | 5
| 2 | 24 | | | | | | | | 4
Case-control studies
Caprioli, Park, Kwon et al., 1997United States Followup: ≥ 24 months Quality: Not Applicable | 1 | 40 | | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0
| 2 | 40
Costa, Smith, Spaeth et al., 1993 United States Followup: 3 to 5 months Quality: Not Applicable | 1 | 16 | | | | 3 | | | | 2
| 2 | 68 | | | | 4 | | | | 6
Donoso, Rodriguez, 2000 Chile Followup: 12 to 23 months Quality: Not Applicable | 1 | 18 | | | | | | 0 | | | 0 | | | | 0 | | 0 | | 0 | 0
| 2 | 22 | | | | | | 0 | | | 0 | | | | 0 | | 0 | | 0 | 0
El-Sayyad, Helal, Khalil et al., 1999 Saudi Arabia Followup: Not Reported Quality: Not Applicable | 1 | 53 | | | 5 | 3 | | | 3 | 6 | 1 | | | | 0 | | | | | 1 | 7
| 2 | 53 | | | 2 | 1 | | | 2 | 5 | 2 | | | | 0 | | | | | 1 | 10
Noben, Linsen, Zeyen, 1998 Europe Followup: 12 to 23 months Quality: Not Applicable | 1 | N.R. | | | 2 | 2 | | | 2 | 2
| 2 | N.R. | | | 2 | 1 | | | 2 | 1
Stewart, Crinkley, Carlson, 1994 United States Followup: Not Reported Quality: Not Applicable | 1 | 15 | | | | 2 | | | | 0 | | 1 | | | | | | 1
| 2 | 16 | | | | 2 | | | | 1 | | 0 | | | | | | 1
Study design: Clinical series
Asamoto, Yablonski, 1993 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | 98 | | | | | | | | 21 | 18
| 2 | 47 | | | | | | | | 11 | 5
| 3 | 12 | | | | | | | | 3 | 4
| 4 | 16 | | | | | | | | 8 | 2
Bloomberg, 1996 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | N.R. | | | | 1 | | | | 51
Burratto, Ferrari, 1990 Europe Followup: 6 to 11 months Quality: Not Applicable | 1 | 104 | | | | | | | 2 | 1 | | | | | | 1 | | | | | 4
Cheung, Wright, Murali et al., 1997 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 157 | | | | 21 | | 2 | | 20 | 5 | | 2 | 4 | | 3 | | | 5 | | 3
Cinotti, Fiore, Maltzman et al., 1998 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 160 | | | | | | | | | | | | | | 2
Crandall, 1991 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 100 | | 1 | | 15 | | 0 | 5 | 16 | | | | | | 2 | | | | | 18
Gunning, Greve, 1991 Europe Followup: 12 to 23 months Quality: Not Applicable | 1 | 102 | | 2 | | 1 | | | | 111 | | | | | | 1 | | | | | 31
Jayamanne, Kostakis, Phelan, 1997 Europe Followup: 6 to 11 months Quality: Not Applicable | 1 | 100 | | | | | | | 4 | 5 | | | | | | 2 | | | | 1
Karlen, Sanchez, Schnyder et al., 1999 Europe Followup: 12 to 23 months Quality: Not Applicable | 1 | 100 | | | 10 | 11 | 0 | 2 | 0 | 7 | 1 | 0 | 0 | 25 | | | 0
Kooner, Dulaney, Zimmerman, 1988 United States Followup: Not Reported Quality: Not Applicable | 1 | 91 | | | | 0 | | | | 4 | | | | | | | | | | | 15
| 2 | 9 | | | | 0 | | | | 1 | | | | | | | | | | | 3
| 3 | 3 | | | | 0 | | | | 1 | | | | | | | | | | | 0
Mamalis, Lohner, Rand et al., 1996 United States Followup: ≥ 24 months Quality: Not Applicable | 1 | 212 | | | | 6 | | | | 28 | | | | | | 5 | | | | | 26
McCartney, Memmen, Stark et al., 1988 United States Followup: Not Reported Quality: Not Applicable | 1 | 108 | | 3 | | 1 | 1 | | | 15 | | | | | | | | | | | 20
Montgomery, Gills, 1980 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 238 | | | | 7 | | | | 112 | | | | | | | | | | | 64
Onali, Raitta, 1991 Europe Followup: ≥ 24 months Quality: Not Applicable | 1 | 103 | | 8 | | | | | 7
Perasalo, 1997 Europe Followup: Not Reported Quality: Not Applicable | 1 | 226 | | 9 | 0 | 0 | 0 | 0 | 2 | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Tanihara, Negi, Akimoto et al., 1993 Japan Followup: ≥ 24 months Quality: Not Applicable | 1 | 439 | | | 0 | 1 | 0 | | | | | 0 | | | 0 | | 0 | | | 0
Tornqvist, Drolsum, 1991 Europe Followup: Not Reported Quality: Not Applicable | 1 | 277 | | | | | 1 | | | 51 | 44
Watson, Jakeman, Ozturk et al., 1990 Europe Followup: ≥ 24 months Quality: Not Applicable | 1 | 150
Yang, Moster, Azuara-Blanco et al., 1997 United States Followup: 12 to 23 months Quality: Not Applicable | 1 | 182 | | | | 5 | 0 | 15 | 0 | 16 | 4 | 0 | 0 | | | 5 | 1 | | 2 | 0 | 22