# Bibliography

Advanced Glaucoma Intervention Study (AGIS): 4. Comparison of treatment outcomes within race. Seven-year results. Ophthalmology. Jul. 1998;105(7):1146-64. [pmid: 9663215].
Alpar J J. Cataract extraction and lens implantation in eyes with pre-existing filtering blebs. Am Intra-Ocular Implant Soc J. Jan. 1979;5:33-5.
Anand N, Menage M J, Bailey C. Phacoemulsification trabeculectomy compared to other methods of combined cataract and glaucoma surgery. Acta Ophthalmol Scand. Dec. 1997;75(6):705-10. [pmid: 9527336].
Anders N, Pham T, Holschbach A, et al. Combined phacoemulsification and filtering surgery with the “no-stitch” technique. Arch Ophthalmol. Oct. 1997;115(10):1245-9. [pmid: 9338668].
Arnold P N. No-stitch phacotrabeculectomy. J Cataract Refract Surg. Mar. 1996;22(2):253-60. [pmid: 8656394].
Asamoto A, Yablonski M E. Posttrabeculectomy anterior subcapsular cataract formation induced by anterior chamber air. Ophthalmic Surg. May. 1993;24(5):314-9. [pmid: 8515947].
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT Statement JAMA. Aug. 1996;276(8):637-9.
Bellucci R, Luraschi M. Trabeculectomy and phacoemulsification: one-way and two-way approach compared after one year. Acta Ophthalmol Scand Suppl 1998;(227):50–1.
Bellucci R, Perfetti S, Babighian S, et al. Filtration and complications after trabeculectomy and after phaco-trabeculectomy. Acta Ophthalmol Scand Suppl 1997;(224):44–5.
Berestka J S, Brown S V. Limbus- versus fornix-based conjunctival flaps in combined phacoemulsification and mitomycin C trabeculectomy surgery. Ophthalmology. Feb. 1997;104(2):187-96. [pmid: 9052621].
Blondeau P, Phelps C D. Trabeculectomy versus thermosclerostomy. A randomized prospective clinical trial. Arch Ophthalmol. May. 1981;99(5):810-6. [pmid: 7236081].
Bloomberg L B. Modified trabeculectomy/trabeculotomy with no-stitch cataract surgery. J Cataract Refract Surg. Jan. 1996;22(1):14-22. [pmid: 8656352].
Bobrow J C. Cataract extraction and lens implantation with and without trabeculectomy: an intrapatient comparison. Trans Am Ophthalmol Soc. 1998;96:521-56. [pmid: 10360303]. [pmcid: 1298409].
Bobrow J C. Prospective intrapatient comparison of extracapsular cataract extraction and lens implantation with and without trabeculectomy. Am J Ophthalmol. Mar. 2000;129:291-6. [pmid: 10704542].
Borggrefe J, Lieb W, Grehn F. A prospective randomized comparison of two techniques of combined cataract - glaucoma surgery. Graefes Arch Clin Exp Ophthalmol. Nov. 1999;237(11):887-92. [pmid: 10541897].
Budenz D L, Pyfer M, Singh K, et al. Comparison of phacotrabeculectomy with 5-fluorouracil, mitomycin-C, and without antifibrotic agents. Ophthalmic Surg Lasers. May. 1999;30(5):367-74. [pmid: 10334024].
Burratto L, Ferrari M. Extracapsular cataract surgery and intraocular lens implantation in glaucomatous eyes that had a filtering bleb operation. J Cataract Refract Surg. May. 1990;16(3):315-9. [pmid: 2355317].
Calissendorff B M, Hamberg-Nystrom H. Pressure control in glaucoma patients after cataract surgery with intraocular lens. Eur J Ophthalmol. Oct. 1992;2(4):163-8. [pmid: 1490087].
Caprioli J, Park HJ, Kwon YH, et al. Temporal corneal phacoemulsification in filtered glaucoma patients. Trans Am Ophthalmol Soc 1997;95:153-67;-discussion 167-170.
Caprioli J, Park H J, Weitzman M. Temporal corneal phacoemulsification combined with superior tabeculectomy: a controlled study. Trans Am Ophthalmol Soc. 1996;94:451-68. [pmid: 8981709]. [pmcid: 1312108].
Carlson D W, Alward W L, Barad J P, et al. A randomized study of mitomycin augmentation in combined phacoemulsification and trabeculectomy. Ophthalmology. Apr. 1997;104(4):719-24. [pmid: 9111269].
Chen P P, Weaver Y K, Budenz D L, et al. Trabeculectomy function after cataract extraction. Ophthalmology. Oct. 1998;105(10):1928-35. [pmid: 9787366].
Cheung J C, Wright M M, Murali S, et al. Intermediate-term outcome of variable dose mitomycin C filtering surgery. Ophthalmology. Jan. 1997;104(1):143-9. [pmid: 9022119].
Chia W L, Goldberg I. Comparison of extracapsular and phaco-emulsification cataract extraction techniques when combined with intra-ocular lens placement and trabeculectomy: short-term results. Aust N Z J Ophthalmol. Feb. 1998;26(1):19-27. [pmid: 9524026].
Cinotti D J, Fiore P M, Maltzman B A, et al. Control of intraocular pressure in glaucomatous eyes after extracapsular cataract extraction with intraocular lens implantation. J Cataract Refract Surg. Nov. 1988;14(6):650-3. [pmid: 3230519].
Cohen J S. Combined cataract implant and filtering surgery with 5-fluorouracil. Ophthalmic Surg. Mar. 1990;21(3):181-6. [pmid: 2348962].
Cohen J S, Greff L J, Novack G D, et al. A placebo-controlled, double-masked evaluation of mitomycin C in combined glaucoma and cataract procedures. Ophthalmology. Nov. 1996;103(11):1934-42. [pmid: 8942892].
Collaborative Normal-Tension Glaucoma Study Group. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. [published erration appears in Am J Ophthalmol 1999 Feb 127:120] Am J Ophthalmol 1998a. Oct;126(4):487-97.
Collaborative Normal-Tension Glaucoma Study Group. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. Am J Ophthalmol. Jan. 1999;127(1):120.
Collaborative Normal-Tension Glaucoma Study Group. The effectiveness of intraocular pressure reduction in the treatment of normal-tension glaucoma. Am J Ophthalmol. Oct. 1998b;126(4):498-505. [pmid: 9780094].
Costa V P, Smith M, Spaeth G L, et al. Loss of visual acuity after trabeculectomy. Ophthalmology. May. 1993;100(5):599-612. [pmid: 8493002].
Crandall A S. Combined trabeculectomy and phacoemulsification. Semin Ophthalmol. Jun. 1991;6(2):76-80. [pmid: 10149517].
Crestani A, De Natale R, Steindler P. Phacotrabeculectomy with or without punch: preliminary results comparing the two techniques. Ophthalmologica. 1997;211:72-4. [pmid: 9097307].
Dastur Y K. The role of early trabeculectomy in the control of chronic simple glaucoma. J Postgrad Med. Apr. 1994;40(2):74-7. [pmid: 8737557].
Demailly P, Kretz G. Daunorubicin versus 5-fluoro-uracil in surgical treatment of primary open angle glaucoma: a prospective study. Int Ophthalmol. Sep. 1992;16(45):367-70. [pmid: 1428573].
Derick R J, Evans J, Baker N D. Combined phacoemulsification and trabeculectomy versus trabeculectomy alone: a comparison study using mitomycin-C. Ophthalmic Surg Lasers. Sep. 1998;29(9):707-13. [pmid: 9760605].
Donoso R, Rodriguez A. Combined versus sequential phacotrabeculectomy with intraopertaive 5-fluorouracil. J Cataract Refract Surg. Jan. 2000;26:71-4. [pmid: 10646149].
Dreyer E B, Chaturvedi N, Zurakowski D. Effect of mitomycin C and fluorouracil-supplemented trabeculectomies on the anterior segment. Arch Ophthalmol. May. 1995;113(5):578-80. [pmid: 7748126].
El-Sayyad F, Helal M, el-Maghraby A, et al. One-site versus 2-site phacotrabeculectomy: a randomized study. J Cataract Refract Surg. Jan. 1999;25(1):77-82. [pmid: 9888081].
El-Sayyad F F, Helal M H, Khalil M M, et al. Phacotrabeculectomy versus two-stage operation: a matched study. Ophthalmic Surg Lasers. Apr. 1999;30(4):260-5. [pmid: 10219028].
Fanous S, Brouillette G. Combined trabeculectomy and cataract extraction: modified technique. Can J Ophthalmol. Oct. 1983;18(6):274-7. [pmid: 6652571].
Galin M A, Hung P T, Obstbaum S A. Cataract extraction in glaucoma. Am J Ophthalmol. Feb. 1979;87(2):124-9. [pmid: 434064].
Galin M A, Obstbaum S A, Asano Y, et al. Laser trabeculoplasty and cataract surgery. Trans Ophthalmol Soc UK. 1985;104(Pt 1):72-5. [pmid: 3855341].
Gandolfi S A, Vecchi M. 5-fluorouracil in combined trabeculectomy and clear-cornea phacoemulsification with posterior chamber intraocular lens implantation. A one-year randomized, controlled clinical trial. Ophthalmology. Feb. 1997;104(2):181-6. [pmid: 9052620].
Garbutt J C, West S L, Carey T S, et al. Pharmacological treatment of alcohol dependence. JAMA. Apr. 1999;281(14):1318-25. [pmid: 10208148].
Gayton J L, Van der Karr M A, Sanders V. Combined cataract and glaucoma procedures using temporal cataract surgery. J Cataract Refract Surg. Dec. 1996;22(10):1485-91. [pmid: 9051507].
Gayton J L, Van Der Karr M, Sanders V. Combined cataract and glaucoma surgery: trabeculectomy versus endoscopic laser cycloablation. J Cataract Refract Surg. Sep. 1999;25(9):1214-9. [pmid: 10476504].
Gianoli F, Schnyder C, Bovey E, et al. Combined surgery for cataract and glaucoma: Phacoemulsification and deep sclerectomy compared with phacoemulsification and trabeculectomy. J Cataract Refract Surg. Mar. 1999;25(3):340-6. [pmid: 10079438].
Gimbel H V, Meyer D, DeBroff B M, et al. Intraocular pressure response to combined phacoemulsification and trabeculotomy ab externo versus phacoemulsification alone in primary open-angle glaucoma. J Cataract Refract Surg. Nov. 1995;21(6):653-60. [pmid: 8551442].
Gunning F P, Greve E L. Intercapsular cataract extraction with implantation of the galand disc lens: a retrospective analysis in patients with and without glaucoma. Ophthalmic Surg. Sep. 1991;22(9):531-8. [pmid: 1945279].
Hayashi K, Hayashi H, Nakao F, et al. Changes in anterior chamber angle width and depth after intraocular lens implantation in eyes with glaucoma. Am Academy Ophthalmol 2000 Apr;698-703.
Hennis H L, Stewart W C. The use of 5-fluorouracil in patients following combined trabeculectomy and cataract extraction. Ophthalmic Surg. Aug. 1991;22(8):451-4. [pmid: 1923295].
Honjo M, Tanihara H, Negi A, et al. Trabeculotomy ab externo, cataract extraction, and intraocular lens implantation: preliminary report. J Cataract Refract Surg. Jun. 1996;22(5):601-6. [pmid: 8784634].
Hopkins J J, Apel A, Trope G E, et al. Early intraocular pressure after phacoemulsification combined with trabeculectomy. Ophthalmic Surg Lasers. Apr. 1998;29(4):273-9. [pmid: 9571658].
Hugkulstone C E, Sadiq S A, Rubasingham A S. The effect of heparin-coated intraocular lenses on intraocular pressure following combined trabeculectomy and cataract surgery. Acta Ophthalmol Scand. Aug. 1997;75(4):437-40. [pmid: 9374256].
Hurvitz L M. 5-FU-supplemented phacoemulsification, posterior chamber intraocular lens implantation, and trabeculectomy. Ophthalmic Surg. Oct. 1993;24(10):674-80. [pmid: 8259245].
Jacobi P C, Dietlein T S, Krieglstein G K. Comparative study of trabecular aspiration versus trabeculectomy in glaucoma triple procedure to treat pseudoexfoliation glaucoma. Arch Ophthalmol. Oct. 1999;117(10):1311-8. [pmid: 10532439].
Javitt J C, Street D A, Tielsch J M, et al. National outcomes of cataract extraction. Retinal detachment and endophthalmitis after outpatient cataract surgery. Cataract patient outcomes research team. Ophthalmology. Jan. 1994;101(1):100-5. [pmid: 8302540].
Jayamanne D G, Kostakis A, Phelan P S. The outcome of 2.3 mm incision combined phacoemulsification, trabeculectomy and lens implantation of non-foldable intraocular lenses. Eye. Feb. 1997;11(Pt 1):91-4. [pmid: 9246284].
Jerndal T, Lundstrom M. 330 trabeculectomies. A long-time study (3–5 1/2 years). Acta Ophthalmol (Copenh). Dec. 1980;58(6):947-56. [pmcid: 358319]. [pmid: 7331781].
Karlen M E, Sanchez E, Schnyder C C, et al. Deep sclerectomy with collagen implant: medium term results. Br J Ophthalmol. Jan. 1999;83(1):6-11. [pmid: 10209426]. [pmcid: 1722768].
Kendrick R, Kollarits C R, Khan N. The results of ab interno laser thermal sclerostomy combined with cataract surgery versus trabeculectomy combined with cataract surgery 6 to 12 months postoperatively. Ophthalmic Surg Lasers. Jul. 1996;27(7):583-6. [pmid: 9240774].
Kim J W, Jung C I, Hwang H S. Comparative study of three phacotrabeculectomy procedures through a single incision. Korean J Ophthalmol. Jun. 1998;12(1):30-6. [pmid: 9753949].
Kitazawa Y, Suemori-Matsushita H, Yamamoto T, et al. Low-dose and high-dose mitomycin trabeculectomy as an initial surgery in primary open-angle glaucoma. Ophthalmology. Nov. 1993;100(11):1624-8. [pmid: 8233386].
Kooner K S, Dulaney D D, Zimmerman T J. Intraocular pressure following ECCE and IOL implantation in patients with glaucoma. Ophthalmic Surg. Aug. 1988;19(8):570-5. [pmid: 3173978].
Kosmin A S, Wishart P K, Ridges P J. Silicone versus poly(methyl methacrylate) lenses in combined phacoemulsification and trabeculectomy. J Cataract Refract Surg. Jan. 1997;23(1):97-105. [pmid: 9100115].
Kosmin A S, Wishart P K, Ridges P J. Long-term intraocular pressure control after cataract extraction with trabeculectomy: phacoemulsification versus extracapsular technique. J Cataract Refract Surg. Feb. 1998;24(2):249-55. [pmid: 9530601].
Krupin T, Feitl M E, Bishop K I. Postoperative intraocular pressure rise in open-angle glaucoma patients after cataract or combined cataract-filtration surgery. Ophthalmology. May. 1989;96(5):579-84. [pmid: 2748112].
Lamping K, Bellows A, Hutchinson B, et al. Long-term evaluation of initial filtration surgery. Ophthalmology. Jan. 1986;93(1):91-101. [pmid: 3951820].
Lemon L C, Shin D H, Kim C, et al. Limbus-based vs fornix-based conjunctival flap in combined glaucoma and cataract surgery with adjunctive mitomycin C. Am J Ophthalmol. Mar. 1998;125(3):340-5. [pmid: 9512151].
Lewis R A, Phelps C D. Trabeculectomy versus thermosclerostomy. A five-year follow-up. Arch Ophthalmol. Apr. 1984;102(4):533-6. [pmid: 6704006].
Liu C J, Su H C, Chou J C, et al. Effect of mitomycin C for combined trabeculectomy and phacoemulsification. Chung Hua I Hsueh Tsa Chih (Taipei). Jan. 2000;63:28-36. [pmid: 10645048].
Luntz M H, Freedman J. The fornix-based conjunctival flap in glaucoma filtration surgery. Ophthalmic Surg. Aug. 1980;11(8):516-21. [pmid: 7422232].
Lyle W A, Jin J C. Comparison of a 3- and 6-mm incision in combined phacoemulsification and trabeculectomy. Am J Ophthalmol. Feb. 1991;111(2):189-96. [pmid: 1992740].
Maltzman B A, Agin M. Argon peripheral iridotomy and cataract formation. Ann Ophthalmol. Jan. 1988;20(1):28-30. [pmid: 3345057].
Mamalis N, Lohner S, Rand A N, et al. Combined phacoemulsification, intraocular lens implantation, and trabeculectomy. J Cataract Refract Surg. May. 1996;22(4):467-73. [pmid: 8733852].
Manoj B, Chako D, Khan M Y. Effect of extracapsular cataract extraction and phacoemulsification performed after trabeculectomy on intraocular pressure. J Cataract Refract Surg. Jan. 2000;26:75-8. [pmid: 10646150].
McCartney D L, Memmen J E, Stark W J, et al. The efficacy and safety of combined trabeculectomy, cataract extraction, and intraocular lens implantation. Ophthalmology. Jun. 1988;95(6):754-63. [pmid: 3211476].
McGuigan L J, Gottsch J, Stark W J, et al. Extracapsular cataract extraction and posterior chamber lens implantation in eyes with preexisting glaucoma. Arch Ophthalmol. Sep. 1986;104(9):1301-8. [pmid: 2875707].
McKinzie J W, Boggs M B. Comparison of postoperative intraocular pressures after use of Miochol and Miostat. J Cataract Refract Surg. Mar. 1989;15(2):185-90. [pmid: 2627210].
McNamara RL, Bass EB, Miller MR et al. Evidence report on management of new onset atrial fibrilation. Evidence report/task order no. 1. Agency for Health Care Policy and Research. 1998; AHCPR Publication No. 99-E021.
Montgomery D, Gills J P. Extracapsular cataract extraction, lens implantation and cyclodialysis. Ophthalmic Surg. May. 1980;11(5):343-7. [pmid: 7383535].
Murchison J F, Shields M B. An evaluation of three surgical approaches for coexisting cataract and glaucoma. Ophthalmic Surg. Jun. 1989;20(6):393-8. [pmid: 2748080].
Murchison J F, Shields M B. Limbal-based versus fornix-based conjunctival flaps in combined extracapsular cataract surgery and glaucoma filtering procedure. Am J Ophthalmol. Jun. 1990;109(6):709-15. [pmid: 2346201].
Naveh N, Kottass R, Glovinsky J, et al. The long-term effect on intraocular pressure of a procedure combining trabeculectomy and cataract surgery, as compared with trabeculectomy alone. Ophthalmic Surg. May. 1990;21(5):339-45. [pmid: 2381656].
Neumann R, Zalish M, Oliver M. Effect of intraocular lens implantation on combined extracapsular cataract extraction with trabeculectomy: a comparative study. Br J Ophthalmol. Oct. 1988;72(10):741-5. [pmid: 3191074]. [pmcid: 1041574].
Nielsen P J. Combined small-incision cataract surgery and trabeculectomy: a prospective study with 1 year of follow-up. Ophthalmic Surg Lasers. Jan. 1997;28(1):21-9. [pmid: 9031301].
Noben K J, Linsen M C, Zeyen T G. Is combined phacoemulsification and trabeculectomy as effective as trabeculectomy alone?. Bull Soc Belge Ophtalmol. 1998;270:85-90. [pmid: 9919785].
O'Connell E J, Karseras A G. Intraocular surgery in advanced glaucoma. Br J Ophthalmol. Feb. 1976;60(2):124-31. [pmid: 1268172]. [pmcid: 1042684].
O'Grady J M, Juzych M S, Shin D H, et al. Trabeculectomy, phacoemulsification, and posterior chamber lens implantation with and without 5-fluorouracil. Am J Ophthalmol. Nov. 1993;116(5):594-9. [pmid: 8238220].
Onali T, Raitta C. Extracapsular cataract extraction and posterior chamber lens implantation in controlled open-angle glaucoma. Ophthalmic Surg. Jul. 1991;22(7):381-7. [pmid: 1891182].
Park H J, Kwon Y H, Weitzman M, et al. Temporal corneal phacoemulsification in patients with filtered glaucoma. Arch Ophthalmol. Nov. 1997;115(11):1375-80. [pmid: 9366666].
Park H J, Weitzman M, Caprioli J. Temporal corneal phacoemulsification combined with superior trabeculectomy. A retrospective case-control study. Arch Ophthalmol. Mar. 1997;115(3):318-23. [pmid: 9076202].
Perasalo R. Phaco-emulsification of cataract in eyes with glaucoma. Acta Ophthalmol Scand. Jun. 1997;75(3):299-300. [pmid: 9253979].
Quigley H S, Vitale S V. Models of open-angle glaucoma prevalence and incidence in the United States. Investigative Ophthalmology and Visual Science. 1997;38:83-91. [pmid: 9008633].
Raitta C, Vesti E. The effect of sodium hyaluronate on the outcome of trabeculectomy. Ophthalmic Surg. Mar. 1991;22(3):145-9. [pmid: 2030895].
Robin A L. Effect of topical apraclonidine on the frequency of intraocular pressure elevations after combined extracapsular cataract extraction and trabeculectomy. Ophthalmology. May. 1993;100(5):628-33. [pmid: 8098520].
Robin A L, Ramakrishnan R, Krishnadas R, et al. A long-term dose-response study of mitomycin in glaucoma filtration surgery. Arch Ophthalmol. Aug. 1997;115(8):969-74. [pmid: 9258217].
Robinson KA, Hinegardner PG, Lansing P. Development of an optimal search strategy for the retrieval of controlled trials using PubMed [abstract]. Proceedings of the 6th International Cochrane Colloquium; 1998 Oct 22–26; Abstr Workshops Sci Sess Int Cochrane Coll. 1998;6:85.
Rossetti L, Bucci L, Miglior S, et al. Temporal corneal phacoemulsification combined with separate-incision superior trabeculectomy versus standard phacotrabeculectomy. A comparative study. Acta Ophthalmol Scand Suppl 1997;(224):39
Sanders S P, Cantor L B, Dobler A A, et al. Mitomycin C in higher risk trabeculectomy: a prospective comparison of 0.2- to 0.4-mg/cc doses. J Glaucoma. Jun. 1999;8(3):193-8. [pmid: 10376260].
Savage J A, Thomas J V, Belcher C D III, et al. Extracapsular cataract extraction and posterior chamber intraocular lens implantation in glaucomatous eyes. Ophthalmology. Nov. 1985;92(11):1506-16. [pmid: 4080323].
Schein OD, Friedman DS, Fleisher LA, et al. Anesthesia management during cataract surgery. Agency for Healthcare Research and Quality (In press). 1999; AHRQ Publication No. 00-0015. Evidence Report/Technology Assessment No. 16 (Contract 290-097-0006 to the Johns Hopkins University Evidence-Based Practice Center).
Shammas H J. Anterior intraocular lens dislocation after combined cataract extraction trabeculectomy. J Cataract Refract Surg. Apr. 1996;22(3):358-61. [pmid: 8778371].
Sharpe E D, Simmons R J. A prospective comparison of Amvisc (TM) and Healon (Reg.trademark) in cataract surgery. J Cataract Refract Surg. Jan. 1986;12(1):47-9. [pmid: 3958952].
Shin D H, Hughes B A, Song M S, et al. Primary glaucoma triple procedure with or without adjunctive mitomycin. Prognostic factors for filtration failure. Ophthalmology. Nov. 1996;103(11):1925-33. [pmid: 8942891].
Shin D H, Kim Y Y, Ren J, et al. Decrease of capsular opacification with adjunctive mitomycin C in combined glaucoma and cataract surgery. Ophthalmology. Jul. 1998;105(7):1222-6. [pmid: 9663225].
Shin D H, Kim Y Y, Sheth N, et al. The role of adjunctive mitomycin C in secondary glaucoma triple procedure as compared to primary glaucoma triple procedure. Ophthalmology. Apr. 1998;105(4):740-5. [pmid: 9544650].
Shin D H, Ren J, Juzych M S, et al. Primary glaucoma triple procedure in patients with primary open-angle glaucoma: the effect of mitomycin C in patients with and without prognostic factors for filtration failure. Am J Ophthalmol. Mar. 1998;125(3):346-52. [pmid: 9512152].
Shin D H, Simone P A, Song M S, et al. Adjunctive subconjunctival mitomycin C in glaucoma triple procedure. Ophthalmology. Oct. 1995;102(10):1550-8. [pmid: 9097805].
Shingleton B J, Chaudhry I M, O'Donoghue M W, et al. Phacotrabeculectomy: limbus-based versus fornix-based conjunctival flaps in fellow eyes. Ophthalmology. Jun. 1999;106(6):1152-5. [pmid: 10366085].
Shingleton B J, Gamell L S, O'Donoghue M W, et al. Long-term changes in intraocular pressure after clear corneal phacoemulsification: normal patients versus glaucoma suspect and glaucoma patients. J Cataract Refract Surg. Jul. 1999;25(7):885-90. [pmid: 10404361].
Shingleton B J, Jacobson L M, Kuperwaser M C. Comparison of combined cataract and glaucoma surgery using planned extracapsular and phacoemulsification techniques. Ophthalmic Surg Lasers. Sep. 1995;26(5):414-9. [pmid: 8963855].
Spaeth G L. A prospective, controlled study to compare the Scheie procedure with Watson's trabeculectomy. Ophthalmic Surg. Oct. 1980;11(10):688-94. [pmid: 7005796].
Steinberg E P, Javitt J C, Sharkey P D, et al. The content and cost of cataract surgery. Arch Ophthalmol. 1993;111(8):1041-9. [pmid: 8352686].
Stewart R H, Loftis M D. Combined cataract extraction and thermal sclerostomy versus combined cataract extraction and trabeculectomy. Ophthalmic Surg. 1976;7(3):93-5. [pmid: 980383].
Stewart W C, Crinkley C M, Carlson A N. Fornix versus limbus-based flaps in combined phacoemulsification and trabeculectomy. Doc Ophthalmol. 1994;88(2):141-51. [pmid: 7781481].
Stewart W C, Crinkley C M, Carlson A N. Results of trabeculectomy combined with phacoemulsification versus trabeculectomy combined with extracapsular cataract extraction in patients with advanced glaucoma. Ophthalmic Surg. Sep. 1994;25(9):621-7. [pmid: 7831007].
Storr-Paulsen A, Pedersen J H, Laugesen C. A prospective study of combined phacoemulsification-trabeculectomy versus conventional phacoemulsification in cataract patients with coexisting open angle glaucoma. Acta Ophthalmol Scand. Dec. 1998;76(6):696-9. [pmid: 9881555].
Tanihara H, Negi A, Akimoto M, et al. Surgical effects of trabeculotomy ab externo on adult eyes with primary open angle glaucoma and pseudoexfoliation syndrome. Arch Ophthalmol. Dec. 1993;111(12):1653-61. [pmid: 8155036].
Tezel G, Kolker A E, Kass M A, et al. Comparative results of combined procedures for glaucoma and cataract: II. Limbus-based versus fornix-based conjunctival flaps. Ophthalmic Surg Lasers. Jul. 1997;28(7):551-7. [pmid: 9243657].
Tezel G, Kolker A E, Kass M A, et al. Comparative results of combined procedures for glaucoma and cataract: I. Extracapsular cataract extraction versus phacoemulsification and foldable versus rigid intraocular lenses. Ophthalmic Surg Lasers. Jul. 1997;28(7):539-50. [pmid: 9243656].
Tezel G, Kolker A E, Kass M A, et al. Late removal of releasable sutures after trabeculectomy or combined trabeculectomy with cataract extraction supplemented with antifibrotics. J Glaucoma. Apr. 1998;7(2):75-81. [pmid: 9559491].
Tielsch JM. Therapy for glaucoma: Costs and consequences in glaucoma. In: Ball S and Franklin R, editors. Diagnosis and Therapy St. Louis: CV Mosby; 1993; p. 61–8.
Tornqvist G, Drolsum L K. Trabeculectomies. A long-term study. Acta Ophthalmol (Copenh). Aug. 1991;69(4):450-4. [pmcid: 358319]. [pmid: 1750313].
Tuulonen A, Niva A K, Alanko H I. A controlled five-year follow-up study of laser trabeculoplasty as primary therapy for open-angle glaucoma. Am J Ophthalmol. Oct. 1987;104(4):334-8. [pmid: 3661640].
Veldman E, Greve E L. Glaucoma filtering surgery, a retrospective study of 300 operations. Doc Ophthalmol. Sep. 1987;67(12):151-70. [pmid: 3428095].
Vu M T, Shields M B. The early postoperative pressure course in glaucoma patients following cataract surgery. Ophthalmic Surg. Jul. 1988;19(7):467-70. [pmid: 3412756].
Vyas A V, Bacon P J, Percival S P. Phacotrabeculectomy: comparison of results from 3.5- and 5.2-mm incisions. Ophthalmic Surg Lasers. Mar. 1998;29(3):227-33. [pmid: 9547777].
Wand M. Combined phacoemulsification, intraocular lens implant, and trabeculectomy with intraoperative mitomycin-C: comparison between 3.2- and 6.0-mm incisions. J Glaucoma. Oct. 1996;5(5):301-7. [pmid: 8897228].
Watson P G, Jakeman C, Ozturk M, et al. The complications of trabeculectomy (a 20-year follow-up). Eye. Jun. 1990;4(Pt 3):425-38. [pmid: 2209905].
Wedrich A, Menapace R, Hirsch U, et al. Comparison of results and complications following combined ECCE-trabeculectomy versus small-incision-trabeculectomy and posterior chamber lens implantation. Int Ophthalmol. Jun. 1996;20(13):125-9. [pmid: 9112176].
West J, Burke J, Cunliffe I, et al. Prevention of acute postoperative pressure rises in glaucoma patients undergoing cataract extraction with posterior chamber lens implant. Br J Ophthalmol. Sep. 1992;76(9):534-7. [pmid: 1420057]. [pmcid: 504343].
Wilson M R. Posterior lip sclerectomy versus trabeculectomy in West Indian blacks. Arch Ophthalmol. Nov. 1989;107(11):1604-8. [pmid: 2684111].
Wishart P K, Austin M W. Combined cataract extraction and trabeculectomy: phacoemulsification compared with extracapsular technique. Ophthalmic Surg. Dec. 1993;24(12):814-21. [pmid: 8115095].
Wong P C, Ruderman J M, Krupin T, et al. 5-fluorouracil after primary combined filtration surgery. Am J Ophthalmol. Feb. 1994;117(2):149-54. [pmid: 8116741].
Wyse T, Meyer M, Ruderman J M, et al. Combined trabeculectomy and phacoemulsification: a one-site versus a two-site approach. Am J Ophthalmol. Mar. 1998;125(3):334-9. [pmid: 9512150].
Yalvac I, Airaksinen P J, Tuulonen A. Phacoemulsification with and without trabeculectomy in patients with glaucoma. Ophthalmic Surg Lasers. Jun. 1997;28(6):469-75. [pmid: 9189950].
Yamagami S, Araie M, Mori M, et al. Posterior chamber intraocular lens implantation in filtered or nonfiltered glaucoma eyes. Jpn J Ophthalmol. 1994;38(1):71-9. [pmid: 7933701].
Yang K J, Moster M R, Azuara-Blanco A, et al. Mitomycin-C supplemented trabeculectomy, phacoemulsification, and foldable lens implantation. J Cataract Refract Surg. May. 1997;23(4):565-9. [pmid: 9209993].
Yu C B, Chong N H, Caesar R H, et al. Long-term results of combined cataract and glaucoma surgery versus trabeculectomy alone in low-risk patients. J Cataract Refract Surg. Apr. 1996;22(3):352-7. [pmid: 8778370].