# Introduction

## Background

Cataract and glaucoma are both common conditions and are often present in the same patient. Cataract surgery is the most commonly performed surgical procedure on Medicare beneficiaries.^1^ Approximately 1.6 million cataract surgeries were performed on Medicare beneficiaries in 1998.^a^ Primary open-angle glaucoma affects at least 2.5 million individuals in the United States.^2^ The total direct cost expenditures for glaucoma therapy have been estimated at $1.56 billion per year.^3^ Although guidelines exist for the indications for cataract surgery in the otherwise healthy eye and for glaucoma surgery in eyes with glaucoma, controversy exists concerning the indications for surgery when both cataract and glaucoma are present. In addition, there is no clear consensus about the appropriate timing of the surgery for each condition, or about the best surgical technique. At the present time, there is no agreement concerning the optimal management of these disorders when coexistent.

The interventions considered in this report are the surgical approaches to the treatment of glaucoma and cataract. For the former, these approaches comprise laser treatment, filtration surgery, and the newer techniques of endoscopic cyclophotocoagulation and the so-called nonpenetrating operations. For cataract surgery, the approaches are corneal and scleral extracapsular extraction using either phacoemulsification or nuclear expression. This report also considers specific medications (i.e., mitomycin-C and 5-fluorouracil) that may be used as ancillary therapy in conjunction with surgical treatment of glaucoma. However, it does not examine the role of glaucoma medications in the treatment of coexisting glaucoma and cataract because our clinical experts felt that it was most important to focus on the surgical treatment options (see the section on Identifying the Specific Questions in Chapter 2).

The affected population is primarily adults, with a predominance of patients over 50 years of age. The estimated size of the affected population in the United States is 100,000 to 150,000 per year. The usual intervention setting is outpatient surgery in a hospital or in an ambulatory surgery center.

The primary outcome for glaucoma is intraocular pressure (IOP), because the reviewed studies were generally of insufficient duration to draw conclusions about optic nerve and visual field changes. Furthermore, few studies reported optic nerve or visual field findings in a manner permitting meaningful analysis.

## Purpose of Evidence Report

The objectives of this evidence report are to: identify the most important questions pertinent to treatment of patients with coexisting cataract and glaucoma; assess the published literature with respect to quality and content regarding these questions; and to inform clinical practitioners and identify areas where future research is needed, based on the literature findings.