# Appendix I - Initial Evidence Grade Assignments

TOPIC | EVIDENCE GRADES
| EB | NC | DF | JK | HJ | LL | HQ | FINAL GRADE | PAGE
CE alone versus CE and glaucoma procedure (long-term) | B+ | A | B | A | A | A | B | A | 36
Limbus- versus fornix-based combined procedures | B | B | B | B | B | B | B | B | 37
Small versus large incision PECE | B | B | B | B | B | B | C (B) | B | 39
PECE plus trabeculectomy versus trabeculectomy alone | C | C | C | B | B | C | C | C | 40
PECE plus trabeculectomy | C | B | B | C | B | C | B | C | 41
ECCE plus trabeculectomy versus trabeculectomy | B | B | C | B | B | C | C | B | 42
ECCE plus trabeculectomy | C | C | B | C | B | C | C | C | 43
ECCE alone | C | B | B | C | B | C | B | C | 44
PECE alone | C | B | B | C | B | C | B | C | 45
CE with functioning filtering bleb | I | | C | B | B | I | C | I | 47
CE alone versus CE plus glaucoma procedure (short-term) | B | B | C | B | B | B | I | I | 49
Adjuvant medications in combined ECCE and trabeculectomy | B | C | C | C | C | C | C | C | 50
PECE combined procedures | C | B | B | C | C | B | I | C | 51
PECE alone | I | | I | | I | I | | I | 51
ECCE combined procedures | I | B | C | C | C | C | B | C | 52
ECCE alone | C | | C | | C | C | | C | 52
Effect of glaucoma surgery on cataract | A- | A | B | A | A | B | A | A | 55
Effect of mitomycin-C on IOP in combined surgery | C | | C | I | B | C | B | B | 60
Effect of 5-FU on IOP in combined surgery | B | A | B | A | A | B | B | B | 63
One- versus two-site procedures | B | | C | B | A | B | C | C | 66
Nuclear expression versus phacoemulsification | C | B | B | C | B | C | I | C | 69
Staged versus combined procedures | I | B | I | I | I | I | C | I | 71
Trabeculectomy versus other procedures | I | B | I | I | I | I | I | I | 73