# Appendix H - List of Questions Addressed by Literature Review and Associated Evidence Tables

Question | Evidence Table
What are the risks and benefits of staged versus combined procedures? | 10
What is the effect of cataract surgery on short-term IOP control in open angle glaucoma? | 5
What is the effect of cataract surgery on long-term IOP control in open angle glaucoma? | 4
What is the effect of glaucoma surgery on the development and progression of cataract? | 6
What are the risks and benefits of mitomycin-C in combined cataract and glaucoma surgery? | 7
What are the risks and benefits of 5-fluorouracil in combined cataract and glaucoma surgery? | 8
What are the risks and benefits of trabeculectomy combined with cataract surgery compared with other types of glaucoma surgery combined with cataract surgery? | 11
What are the risks and benefits of single-site versus two-site operations? | 9
What are the risks and benefits of nuclear expression versus phacoemulsification in combined cataract and glaucoma surgery? | 9