# Appendix D - Priority Journals

Coverage in Databases as of January 24, 2000

Journal Name | Cochrane Handsearching (dates of registered searches) ^a^ | PubMed (date, volume and issue of most recent citation)
American Journal of Ophthalmology | 1970, 1981, 1985-1998 | Dec 1999 128(6)
Archives of Ophthalmology | 1964-1998 | Jan 2000 118(1)
Journal of Cataract and Refractive Surgery | 1993-1995 | Dec 1999 25(12)
Journal of Glaucoma | 1992-present | Dec 1999 8(6)
Ophthalmology | 1970, 1978-1998 | Dec 1999 106(12)

a Note: In addition to handsearching, the Cochrane Collaboration also searches electronic databases, such as MEDLINE and EMBASE, for controlled trials.