# Appendix C - PubMed Core Strategy

((((((“cataract”[mh] OR cataract[tw]) AND (“glaucoma”[mh] OR glaucoma[tw])) AND (((((((((“surgery”[mh] OR surgery[tw]) OR “filtering surgery”[mh]) OR filtering surgery[tw]) OR “cataract extraction”[mh]) OR cataract extraction[tw]) OR sclerostomy[tw]) OR trabeculectomy[tw]) OR phacoemulsification[tw]) NOT ((“child”[mh] OR “anesthesia”[mh]) OR “anesthetics”[mh])))

- limited to English [la]
- added to all phases of PubMed optimal search strategy for retrieval of controlled trials, with addition of search strategy for case series

## Optimal search strategy for the retrieval of controlled trials using PubMed: Phases 1, 2 and 3^a.^ a. Robinson KA, Hinegardner PG, Lansing P. Development of an optimal search strategy for the retrieval of controlled trials using PubMed [abstract]. Proceedings of the 6th International Cochrane Colloquium; 1998 Oct 22–26; Abstr Workshops Sci Sess Int Cochrane Coll. 1998;6:85.

(randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh] OR clinical trial [pt] OR clinical trials [mh] OR (clinic* [tw] AND trial* [tw]) OR ((singl* [tw] OR doubl* [tw] OR trebl* [tw] OR tripl* [tw]) AND (mask* [tw] OR blind* [tw])) OR (latin [tw] AND square [tw]) OR placebos [mh] OR placebo* [tw] OR random* [tw] OR research design [mh:noexp] OR comparative study [mh] OR evaluation studies [mh] OR follow-up studies [mh] OR prospective studies [mh] OR cross-over studies [mh] OR control* [tw] OR prospectiv* [tw] OR volunteer* [tw] OR [underlined: case report[mh] OR (case[tw] AND series[tw]])) NOT (animal [mh] NOT human [mh])

note: items underlined added to strategy for the glaucoma EPC literature search