# Appendix B - Question Refinement Mailing

## Potential Topics for Evidence-Based Report Treatment of Coexisting glaucoma and Cataract Name

The Johns Hopkins University Evidence-based Practice Center will be developing an Evidence Report on Treatment of Coexisting Glaucoma and Cataract for the Agency for Healthcare Research and Quality of the U.S. Department of Health and Human Services. We are soliciting input from experts with varied perspectives on key questions regarding management of coexisting cataract and glaucoma.

PLEASE ASSIST US IN IDENTIFYING, FROM YOUR PERSPECTIVE AS _________________, WHAT ARE THE MOST IMPORTANT QUESTIONS THAT SHOULD BE ADDRESSED.

Please return your form to Dr. Lisa Lubomski at (410) 614-9651 (fax), by December 13^th^. Should you have any questions, please call us at (410) 614-4037 or e-mail (llubomski@jhmi.edu).

Please read the following eight questions regarding treatment of coexisting glaucoma and cataract and rank each question below as follows: (1) crucial, (2) desirable, or (3) unimportant, for in-depth examination in our study. Please write in the space provided any other questions that you think are particularly relevant or controversial.

Possible Questions | Rank | Comments
1. What is the effect of glaucoma surgery (i.e., filtration surgery) upon the development and progression of cataract?
2. What is the effect of cataract surgery upon short and long-term intraocular pressure control in open angle glaucoma patients?
3. What are the risks and benefits of the alternative surgical techniques for operating on eyes with both cataract and glaucoma:
a) Staged procedure versus combined?
b) With anti-fibrosis agent or without anti-fibrosis agent?
c) Single site for both operations or two sites?
d) Trabeculectomy versus endoscopic laser versus deep sclerectomy/viscocanulostomy?
e) Nuclear expression or phacoemulsification?
(OTHER)

How might your organization use an evidence report on Treatment of Coexisting Glaucoma and Cataract? Check all that apply

- Would use report to facilitate development of a new practice guideline on surgical treatment of patients with coexisting glaucoma and cataract.
- Would use report to assess the appropriateness of your organization's existing guidelines on management of patients with coexisting glaucoma and cataract.
- Would use report to prepare educational materials for physicians.
- Would use report to prepare educational materials for patients.
- Other (please specify)____________________________________
- Other (please specify)____________________________________
- Other Comments?_____________________________________________________________
  ___________________________________________________________________________
  ___________________________________________________________________________
  ________
- Signature of person completing form: __________________________________________